# Appendix E - Field Reviewers

- Ruth Airey-Vidal
- Coordinator
- Wellness Initiative for Senior Educators
- Sussex Council on Alcohol and Drug Abuse
- Newton, New Jersey

- Sharon Amatteti
- Public Health Analyst
- Office of Policy Coordination and Planning
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Mary Candace Burger, Ph.D.
- Assistant Professor
- Division of Geriatric Psychiatry
- Department of Psychiatry
- Vanderbilt Medical School
- Nashville, Tennesee

- James Donagher
- Director
- Senior Services
- Special Populations of Office of Behavioral Health
- Department of Mental Health and Addiction Services
- Hartford, Connecticut

- Charles M. Donahue, M.Div.
- Community Liaison
- Behavioral Health Network
- Alexian Brothers Hospital
- Saint Louis, Missouri

- Nancy L. Erckenbrack
- Regional Director
- Operations and Housing
- Long-Term Care Division
- Providence Health Systems
- Portland, Oregon

- Hugh Everman
- Staff Assistant
- Department of Sociology
- Morehead State University
- Morehead, Kentucky

- Robert S. Geissinger
- Counselor
- Division of Alcoholism and Substance Abuse
- Washington State Department of Social and
- Health Services
- Lacey, Washington

- Charles V. Giannasio, M.D.
- Senior Consultant for Addictive Disorders
- Northwest Institute of Psychiatry
- Jenkintown, Pennsylvania

- Robert K. Heaton, Ph.D.
- Professor of Psychiatry
- Neuropsychology Laboratory
- University of California at San Diego
- San Diego, California

- Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- Ronald J. Hunsicker
- Executive Director
- National Association of Addiction Treatment Providers
- Lititz, Pennsylvania

- Carol L. Joseph, M.D.
- Associate Chief
- Staff for Geriatric and Extended Care
- Honolulu VAMROC
- Honolulu, Hawaii

- Joseph Liberto, M.D.
- Director
- UAMC
- Baltimore, Maryland

- Jane E. Myers, Ph.D.
- Professor
- Department of Counseling and
- Educational Development
- University of North Carolina at Greensboro
- Greensboro, North Carolina

- Reba L. Novich, M.S.W.
- Resource Manager
- National Resource Center
- Osteoporosis and Related Bone Diseases
- Washington, D.C.

- Robert Rawlings
- Director
- OBRA and LTC
- Community Programs
- Oklahoma Department of Mental Health
- and Substance Abuse Services
- Oklahoma City, Oklahoma

- Patricia Reihl
- Coordinator
- Spring House
- Paramus, New Jersey

- Anita Rosen, Ph.D.
- Senior Staff Associate for Aging
- National Association of Social Workers
- Washington, D.C.

- Margaret M. Salinger, M.S.N., R.N., C.A.R.N.
- National Nurses Society on Addiction
- c/o Department of Veterans Affairs Medical Center
- Coatesville, Pennsylvania

- Eleanor Sargent
- Director
- Clinical Issues
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Timothy M. Scanlan
- President
- Addiction Specialists of Kansas
- Wichita, Kansas

- Larry I. Schonfeld, Ph.D.
- Professor
- Department of Aging and Mental Health
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- Anthony Sims
- Acting Director
- Office of Communications and External Liaison
- Center for Substance Abuse Treatment
- Rockville, Maryland

- Richard T. Suchinsky, M.D.
- Associate Chief
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- David O. Turner
- Program Manager
- Health Aging Program
- Salt Lake County Aging Services
- Salt Lake City, Utah

- John W. Welte, Ph.D.
- Research Scientist
- Research Institute on Addiction
- Buffalo, New York

- Larry W. Whorley
- Program Coordinator
- Substance Abuse Treatment Program
- Lexington, Kentucky