# Appendix D - Resource Panel

- Kathleen Austin, CDC III, NCAC II
- Alcohol Therapist II
- Adult Medicine/Ambulatory Care
- Harborview Medical Center
- Seattle, Washington

- James D. Baxendale, Ph.D.
- Deputy Director
- Quality Assurance and Case Management
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.

- Gwendolyn G. Bennett
- Special Assistant to the Director
- Division of State and Community Systems Development
- Center for Mental Health Services
- Rockville, Maryland

- Gayle Boyd, Ph.D.
- Health Scientist Administrator
- Prevention Research Branch
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Mildred Brooks-McDow, M.S.W., L.I.C.S.W.
- Public Health Advisor
- Division of State and Community Systems Development
- Center for Mental Health Services
- Rockville, Maryland

- Carol Cober
- Acting Manager
- Social Outreach and Support Division
- American Association of Retired Persons
- Washington, D.C.

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Betty Davis
- Senior Project Specialist
- Social Outreach and Support Division
- American Association of Retired Persons
- Washington, D.C.

- Loretta Finnegan, M.D.
- Director
- Women's Health Initiative
- National Institutes of Health
- Bethesda, Maryland

- Linda S. Foley, M.A.
- Member
- TIPS Editorial Advisory Board
- Director
- Treatment Improvement Exchange
- Health Systems Research, Inc.
- Washington, D.C.

- Rizalina C. Galicinao
- Program Analyst
- Office of Minority Health
- Public Health Service
- Rockville, Maryland

- Deborah Horan
- Manager
- Special Issues
- American College of Obstetrics and Gynecology
- Washington, D.C.

- Alixe McNeill
- Senior Program Manager
- National Council on the Aging
- Washington, D.C.

- Reba L. Novich, M.S.W.
- Resource Manager
- National Resource Center
- Osteoporosis and Related Bone Diseases
- Washington, D.C.

- Hila Richardson, Dr.P.H.
- Deputy Director
- Medical Research and Practice Policy
- National Center on Addiction and Substance Abuse
- Columbia University
- New York, New York

- Anita Rosen, Ph.D.
- Senior Staff Associate for Aging
- National Association of Social Workers
- Washington, D.C.

- Eleanor Sargent
- Director
- Clinical Issues
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Joanne G. Schwartzberg, M.D.
- Director
- Department of Geriatric Health
- American Medical Association
- Chicago, Illinois

- Doralie L. Segal, M.S.
- Senior Advisor
- PHS Office of Women's Health
- Medical Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Nancy J. Wartow
- Policy Specialist
- Administration on Aging
- Washington, D.C.

- Paul Wohlford, Ph.D.
- Acting Branch Chief
- Division of State and Community Systems Development
- Center for Mental Health Services
- Rockville, Maryland