# Appendix B - Tools

Appendix B contains the following items:

- The Alcohol Use Disorders Identification Test (AUDIT)
- Index of Activities of Daily Living (Index of ADLs)
- Instrumental Activities of Daily Living (IADL) Scale
- Geriatric Depression Scale (GDS) Short Form
- Center for Epidemiologic Studies - Depression Scale (CES-D)
- Health Screening Survey (HSS), Revised.

## The Alcohol Use Disorders Identification Test (AUDIT)

The following guidelines, questions, and scoring instructions are excerpted from Babor, T.F.; de la Fuente, J.R.; Saunders, J.; and Grant, M. AUDIT: The Alcohol Use Disorders Identification Test: Guidelines for Use in Primary Health Care. Geneva, Switzerland: World Health Organization, 1992.

### How To Use AUDIT

Screening with AUDIT can be conducted in a variety of primary care settings by persons who have different kinds of training and professional backgrounds. The core AUDIT is designed to be used as a brief structured interview or self-report survey that can easily be incorporated into a general health interview, lifestyle questionnaire, or medical history. When presented in this context by a concerned and interested interviewer, few patients will be offended by the questions. The experience of the WHO collaborating investigators (Saunders and Aasland, 1987) indicated that AUDIT questions were answered accurately regardless of cultural background, age, or gender. In fact, many patients who drank heavily were pleased to find that a health worker was interested in their use of alcohol and the problems associated with it.

In some patients, the AUDIT questions may not be answered accurately because they refer specifically to alcohol use and problems. Some patients may be reluctant to confront their alcohol use or to admit that it is causing them harm. Individuals who feel threatened by revealing this information to a health worker, who are intoxicated at the time of the interview, or who have certain kinds of mental impairment may give inaccurate responses. Patients tend to answer most accurately when

- The interviewer is friendly and nonthreatening
- The purpose of the questions is clearly related to a diagnosis of their health status
- The patient is alcohol- and drug-free at the time of the screening
- The information is considered confidential
- The questions are easy to understand.

Health workers should try to establish these conditions before AUDIT is given. When these conditions are not present, the Clinical Screening Instrument following the AUDIT questionnaire may be more useful. Alternatively, health workers may also use AUDIT to guide an interview with a concerned friend, spouse, or family member. In some settings (such as waiting rooms), AUDIT may be administered as a self-report questionnaire, with instructions for the patient to discuss the meaning of the results with the primary care worker. In addition to these general considerations, the following interviewing techniques should be used:

- Try to interview patients under the best possible circumstances. For patients requiring emergency treatment or who are severely impaired, it is best to wait until their condition has stabilized and they have become accustomed to the health setting where the interview is to take place.
- Look for signs of alcohol or drug intoxication. Patients who have alcohol on their breath or who appear intoxicated may be unreliable respondents. Consider conducting the interview at a later time. If this is not possible, make note of these findings on the patient's record.
- If AUDIT is embedded, as recommended, in a longer health interview, then a transitional statement will be needed when the AUDIT questions are asked. The best way to introduce the AUDIT questions is to give the patient a general idea of the content of the questions, the purpose for asking them, and the need for accurate answers. The following is an illustrative introduction: "Now I am going to ask you some questions about your use of alcoholic beverages during the past year. Because alcohol use can affect many areas of health (and may interfere with certain medications), it is important for us to know how much you usually drink and whether you have experienced any problems with your drinking. Please try to be as honest and as accurate as you can be." This statement should be followed by a description of the types of alcoholic beverages typically consumed in the population to which the patient belongs (e.g., "By alcoholic beverages we mean your use of wine, beer, vodka, sherry, and so on."). If necessary, include a description of beverages that may not be considered alcoholic (e.g., cider, low alcohol beer).
- It is important to read the questions as written and in the order indicated. By following the exact wording, better comparability will be obtained between your results and those obtained by other interviewers.
- Most of the questions in AUDIT are phrased in terms of "how often" symptoms occur. It is useful to offer the patient several examples of the response categories (for example, "Never," "Several times a month," "Daily") to suggest how he might answer. When he has responded, it is useful to probe during the initial questions to be sure that the patient has selected the most accurate response (for example, "You say you drink several times a week. Is this just on weekends or do you drink more or less every day?"). If responses are ambiguous or evasive, continue asking for clarification by repeating the question and the response options, asking the patient to choose the best one. At times, answers are difficult to record because the patient may not drink on a regular basis. For example, if the patient was drinking intensively for the month prior to an accident, but not before or since, then it will be difficult to characterize the "typical" drinking sought by the question. In these cases it is best to record the amount of drinking and related symptoms for the heaviest drinking period of the past year, making note of the fact that this may be atypical or transitory for that individual.

Record answers carefully, using the comments section of the interview brochure to explain any special circumstances, additional information, or clinical inferences. Often patients will provide the interviewer with useful comments about their drinking that can be valuable in the interpretation of the total AUDIT score.

### The AUDIT Questionnaire

The AUDIT Questionnaire
Circle the number that comes closest to the patient's answer. 1. How often do you have a drink containing alcohol?
(0) Never | (1) Monthly or less | (2) Two to four times a month | (3)Two to three times a week | (4)Four or more times a week
2. How many drinks containing alcohol do you have on a typical day when you are drinking? [Code number of standard drinks.^1^
(0) 1 or 2 | (1) 3 or 4 | (2 5 or 6 | (3) 7 to 9 | (4)10 or more
3. How often do you have six or more drinks on one occasion?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4) Daily or almost daily
4. How often during the last year have you found that you were not able to stop drinking once you had started?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4)Daily or almost daily
5. How often during the last year have you failed to do what was normally expected from you because of drinking?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4)Daily or almost daily
6. How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4)Daily or almost daily
7. How often during the last year have you had a feeling of guilt or remorse after drinking?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4)Daily or almost daily
8. How often during the last year have you been unable to remember what happened the night before because you had been drinking?
(0) Never | (1) Less than monthly | (2) Monthly | (3)Weekly | (4)Daily or almost daily
9. Have you or someone else been injured as a result of your drinking?
(0) No | (2) Yes, but not in the last year | (4)Yes, during the last year
10. Has a relative or friend or a doctor or other health worker been concerned about your drinking or suggested you cut down?
(0) No | (2) Yes, but not in the last year | (4)Yes, during the last year

### Procedure for scoring AUDIT

Procedure for scoring AUDIT
Questions 1-8 are scored 0, 1, 2, 3, or 4. Questions 9 and 10 are scored 0, 2, or 4 only. The response is as follows:
| 0 | 1 | 2 | 3 | 4
Question 1 | Never | Monthly or less | Two to four times per month | Two to three times per week | Four or more times per week
Question 2 | 1 or 2 | 3 or 4 | 5 or 6 | 7 to 9 | 10 or more
Question 3-8 | Never | Less than monthly | Monthly | Weekly | Daily or almost daily
Question 9-10 | No | | Yes, but not in the last year | | Yes, during the last year

### AUDIT "Clinical" Questions and Procedure

AUDIT "Clinical" Questions and Procedure
Trauma history
1. Have you injured your head since your 18th birthday?
(3) Yes | | (0) No
2. Have you broken any bones since your 18th birthday?
(3) Yes | | (0) No
Clinical examination
1. Conjunctival injections
(0) NOT PRESENT | (1) MILD | (2) MODERATE | (3) SEVERE
2. Abnormal skin vascularization
(0) NOT PRESENT | (1) MILD | (2) MODERATE | (3) SEVERE
3. Hand tremor
(0) NOT PRESENT | (1) MILD | (2) MODERATE | (3) SEVERE
4. Tongue tremor
(0) NOT PRESENT | (1) MILD | (2) MODERATE | (3) SEVERE
5. Hepatomegaly
(0) NOT PRESENT | (1) MILD | (2) MODERATE | (3) SEVERE
GGT Values* | Lower normal | (0-30 IU/1)=(0)
| Upper normal | (30-50 IU/1)=(1)
| Abnormal | (50 IU/1)=(3)

*These values may change with laboratory methods, and standards may vary with sex and age of the drinker.

Record sum of individual item scores here. ____________________________

### Scoring and Interpretation of AUDIT

As indicated by the AUDIT questions, each item is scored by checking the response category that comes closest to the patient's answer.

On the basis of evidence from the validation study (Saunders et al., in press), two cutoff points are suggested, depending on the purpose of the screening program or the nature of the research project. A score of 8 or more produces the highest sensitivity, while a score of 10 or more results in higher specificity. In general, high scores on the first three items in the absence of elevated scores on the remaining items suggest hazardous alcohol use. Elevated scores on items 4 through 6 imply the presence or emergence of alcohol dependence. High scores on the remaining items suggest harmful alcohol use. As discussed in the following section on diagnosis, each of these areas of alcohol-related problems implies different types of management.

The Clinical Screening Instrument is considered to be elevated when the total score is 5 or greater. Here, too, the examiner should give careful consideration to the different meanings attributed to alcohol-related trauma, physical signs, and the elevated liver enzyme. It should be noted that false positives can occur when the individual is accident prone, uses drugs (such as barbiturates) that induce GGT, or has hand tremor because of nervousness, neurological disorder, or nicotine dependence.

### References

- Saunders, J.B., and Aasland, O.G.
- WHO Collaborative Project on the Identification and Treatment of Persons with Harmful Alcohol Consumption. Report on Phase I: Development of a Screening Instrument. Geneva, Switzerland: World Health Organization, 1987.

- Saunders, J.B.; Aasland, O.G.; Babor, T.F.; de la Fuente, J.R.; and Grant, M.
- WHO collaborative project on early detection of persons with harmful alcohol consumption. II. Development of the screening instrument "AUDIT." British Journal of Addictions, in press.

## Index of Activities of Daily Living (ADLs)

### Index of Independence in Activities of Daily Living

The Index of Independence in Activities of Daily Living is based on an evaluation of the functional independence or dependence of patients in bathing, dressing, going to the toilet, transferring, continence, and feeding. Specific definitions of functional independence and dependence appear below the index. (These definitions can be used to convert the data recorded in the evaluation form in the next section into an Index of ADL grade.)

A--Independent in feeding, continence, transferring, going to the toilet, dressing, and bathing.

B--Independent in all but one of these functions.

C--Independent in all but bathing and one additional function.

D--Independent in all but bathing, dressing, and one additional function.

E--Independent in all but bathing, dressing, going to the toilet, and one additional function.

F--Independent in all but bathing, dressing, going to toilet, transferring, and one additional function.

G--Dependent in all six functions.

Other--Dependent in at least two functions, but not classifiable as C, D, E, or F.

Independence means without supervision, direction, or active personal assistance, except as specifically noted below. This is based on actual status and not on ability. A patient who refuses to perform a function is considered as not performing the function, even though he is deemed able.

Bathing (Sponge, Shower, or Tub)

Independent: assistance only in bathing a single part (as back or disabled extremity) or bathes self completely

Dependent: assistance in bathing more than one part of body; assistance in getting in or out of tub or does not bathe self

Dressing

Independent: gets clothes from closets and drawers; puts on clothes, outer garments, braces; manages fasteners; act of tying shoes is excluded

Dependent: does not dress self or remains partly undressed

Going to Toilet

Independent: gets to toilet; gets on and off toilet; arranges clothes; cleans organs of excretion; (may manage own bedpan used at night only and may or may not be using mechanical supports)

Dependent: uses bedpan or commode or receives assistance in getting to and using toilet

Transfer

Independent: moves in and out of bed independently and moves in and out of chair independently (may or may not be using mechanical supports)

Dependent: assistance in moving in or out of bed and/or chair; does not perform one or more transfers

Continence

Independent: urination and defecation entirely self-controlled

Dependent: partial or total incontinence in urination or defecation, partial or total control by enemas, catheters, or regulated use of urinals and/or bedpans

Feeding

Independent: gets food from plate or its equivalent into mouth; (precutting of meat and preparation of food, as buttering bread, are excluded from evaluation)

Dependent: assistance in act of feeding (see above); does not eat at all or parental feeding

### Evaluation Form

Name_________________________ Day of Evaluation________________________

For each area of functioning listed below, check description that applies. (The word "assistance" means supervision, direction, or personal assistance.)

Bathing--either sponge bath, tub bath, or shower.

- Receives no assistance (gets in and out of tub by self if tub is usual means of bathing)
- Receives assistance in bathing only one part of the body (such as back or a leg)
- Receives assistance in bathing more than one part of the body (or not bathed)

Dressing--gets clothes from closets and drawers--including underclothes, outer garments, and using fasteners (including braces if worn)

- Gets clothes and gets completely dressed without assistance
- Gets clothes and gets dressed without assistance except for assistance in tying shoes
- Receives assistance in getting clothes or in getting dressed, or stays partially or completely undressed

Toileting--going to the "toilet room" for bowel and urine elimination, cleaning self after elimination, and arranging clothes

- Goes to "toilet room," cleans self, and arranges clothes without assistance (may use object for support such as cane, walker, or wheelchair and may manage night bedpan or commode emptying same in morning)
- Receives assistance in going to "toilet room" or in cleansing self or in arranging clothes after elimination or in use of night bedpan or commode
- Doesn't go to room termed "toilet" for the elimination process

Transfer--

- Moves in and out of bed as well as in and out of chair without assistance (may be using object for support such as cane or walker)
- Moves in and out of bed or chair with assistance
- Doesn't get out of bed

Continence--

- Controls urination and bowel movement completely by self
- Has occasional "accidents"
- Supervision helps keep urine or bowel control; catheter is used, or is incontinent

Feeding--

- Feeds self without assistance
- Feeds self except for getting assistance in cutting meat or buttering bread
- Receives assistance in feeding or is fed partly or completely by using tubes or intravenous fluids

After filling out the form, convert the data collected into an ADL grade by using the definitions provided in the introductory section.

Source: Katz, S.; Ford, A.B.; Moskowitz, R.W.; Jackson, B.A.; and Jaffe, M.W. Studies of Illness in the Aged. The Index of ADL: A standardized measure of biological and psychosocial function. Journal of the American Medical Association 185:914-919, 1963.

### References

- Katz, S.; Downs, T.D.; Cash, H.R.; and Grotz, R.C.
- Progress in development of the Index of ADL. Gerontologist 10(1):20-30, 1970.

- Katz, S., and Akpom, C.A.
- Index of ADL. Medical Care 14(suppl. 5):116-118. 1976.

## Instrumental Activities of Daily Living (IADL) Scale

Self-Rated Version Extracted From the Multilevel Assessment Instrument (MAI)
1. | Can you use the telephone:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to use the telephone? | 1
2. | Can you get to places out of walking distance:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to travel unless special arrangements are made? | 1
3. | Can you go shopping for groceries:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to do any shopping? | 1
4. | Can you prepare your own meals:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to prepare any meals? | 1
5. | Can you do your own housework:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to do any housework? | 1
6. | Can you do your own handyman work:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to do any handyman work? | 1
7. | Can you do your own laundry:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to do any laundry at all? | 1
8a. | Do you take any medications or use any medications?
| (ASK Q. 8b) Yes | 1
| (ASK Q. 8c) No | 2
8b. | (ASK IF SUBJECT TAKES MEDICINE NOW)
| Do you take your own medicine: (CHECK BELOW)
8c. | (ASK IF SUBJECT DOES NOT TAKE MEDICINE NOW)
| If you had to take medicine, can you do it: (CHECK BELOW)
| Without help (in the right doses at the right time), | 3
| With some help (take medicine if someone prepares it for you and/or reminds you to take it), or | 2
| (Are you/would you be) completely unable to take your own medicines? | 1
9. | Can you manage your own money:
| Without help, | 3
| With some help, or | 2
| Are you completely unable to handle money? | 1

Note on Scoring:

If fewer than 5 items are valid, then scoring cannot be done reliably.

Source: Lawton, M.P.; Moss, M.; Fulcomer, M.; and Kleban, M.H. A research and service-oriented Multilevel Assessment Instrument. Journal of Gerontology 37:91-99, 1982.

### References

- Lawton, M.P.
- Scales to measure competence in everyday activities. Psychopharmacology Bulletin 24(4):609-614, 1988.

- Lawton, M.P., and Brody, E.M.
- Assessment of older people: Self-maintaining and instrumental activities of daily living. Gerontologist 9:179-186, 1969.

- Reproduced with permission from M. Powell Lawton, Ph.D.

## Geriatric Depression Scale (GDS) Short Form

Choose the best answer for how you have felt over the past week:

1. Are you basically satisfied with your life? YES/NO
2. Have you dropped many of your activities and interests? YES/NO
3. Do you feel that your life is empty? YES/NO
4. Do you often get bored? YES/NO
5. Are you in good spirits most of the time? YES/NO
6. Are you afraid that something bad is going to happen to you? YES/NO
7. Do you feel happy most of the time? YES/NO
8. Do you often feel helpless? YES/NO
9. Do you prefer to stay at home, rather than going out and doing new things? YES/NO
10. Do you feel you have more problems with memory than most? YES/NO
11. Do you think it is wonderful to be alive now? YES/NO
12. Do you feel pretty worthless the way you are now? YES/NO
13. Do you feel full of energy? YES/NO
14. Do you feel that your situation is hopeless? YES/NO
15. Do you think that most people are better off than you are? YES/NO

Answers in bold indicate depression, and each answer counts as one point. For clinical purposes, a score greater than 5 suggests depression and warrants a followup interview. Scores greater than 10 are almost always depression.

Source: Sheikh, J.I., and Yesavage, J.A. Geriatric Depression Scale (GDS): Recent evidence and development of a shorter version. Clinical Gerontologist 5(1&2):165-173, 1986.

### References

- Brink, T.L.; Yesavage, J.A.; Lum, O.; Heersema, P.; Adey, M.B.; and Rose, T.L.
- Screening tests for geriatric depression. Clinical Gerontologist 1:37-44, 1982.

- Yesavage, J.A.; Brink, T.L.; Rose, T.L.; Lum, O.; Huang, V.; Adey, M.B.; and Leirer, V.O.
- Development and validation of a geriatric depression screening scale: A preliminary report. Journal of Psychiatric Research 17:37-49, 1983.

## The Center for Epidemiologic Studies Depression Scale (CES-D)

For the 20 items below, circle the number next to each item that best reflects how frequently the indicated event was experienced in the past 7 days.

| | Rarely or none of the time (Less than 1 Day) | Some or a little of the time (1--2 days) | Occasionally or a moderate amount of time (3--4 Days) | Most or all of the time (5--7 Days)
DURING THE PAST WEEK:
1. | I was bothered by things that usually don't bother me. | 0 | 1 | 2 | 3
2. | I did not feel like eating: my appetite was poor. | 0 | 1 | 2 | 3
3. | I felt that I could not shake off the blues even with help from my family or friends. | 0 | 1 | 2 | 3
4. | I felt that I was just as good as other people. | 0 | 1 | 2 | 3
5. | I had trouble keeping my mind on what I was doing. | 0 | 1 | 2 | 3
6. | I felt depressed. | 0 | 1 | 2 | 3
7. | I felt that everything I did was an effort. | 0 | 1 | 2 | 3
8. | I felt hopeful about the future. | 0 | 1 | 2 | 3
9. | I thought my life had been a failure. | 0 | 1 | 2 | 3
10. | I felt fearful. | 0 | 1 | 2 | 3
11. | My sleep was restless. | 0 | 1 | 2 | 3
12. | I was happy. | 0 | 1 | 2 | 3
13. | I talked less than usual. | 0 | 1 | 2 | 3
14. | I felt lonely. | 0 | 1 | 2 | 3
15. | People were unfriendly. | 0 | 1 | 2 | 3
16. | I enjoyed life. | 0 | 1 | 2 | 3
17. | I had crying spells. | 0 | 1 | 2 | 3
18. | I felt sad. | 0 | 1 | 2 | 3
19. | I felt that people disliked me. | 0 | 1 | 2 | 3
20. | I could not get "going." | 0 | 1 | 2 | 3

## Health Screening Survey (HSS), Revised

Check the appropriate answer
1. In the last three months, have you been dieting to lose weight?
| ___YES | ___NO
IF YES: How many pounds have you managed to lose?
| ___0 | ___1 - 3 | ___4 - 7 | ___8 or more
2. In the last three months, have you performed physical activity or exercise in your leisure time at least 20 minutes without stopping, enough to make you breathe hard and/or sweat?
| ___YES | ___NO
IF YES: On average, how many days per week have you been exercising
| ___1 - 2 | ___3 - 4 | ___5 - 6 | ___Every day
3. In the last three months, have you been smoking cigarettes at all?
| ___YES | ___NO
IF YES: On average, how many cigarettes have you been smoking each day?
| ___1 - 9 | ___10 - 19 | ___20 - 29 | ___30 or more
4. In the last three months, have you been drinking alcoholic drinks at all (e.g., beer, wine, sherry, vermouth, or hard liquor)?
| ___YES | ___NO
IF NO, go to question 5.
IF YES, ANSWER 4a through 4c.
4a. On average, how many days per week have you been drinking beer or wine coolers?
___None | ___1 - 2 | ___3 - 4 | ___5 - 6 | ___Every day
On a day when you have had wine, sherry, or vermouth to drink, how many glasses, bottles, or cans have you been drinking?
___1 - 2 | ___3 - 4 | ___5 - 8 | ___9 - 14 | ___15 or more
AND
4b. On average how many days per week have you been drinking wine, sherry, or vermouth?
___None | ___1 - 2 | ___3 - 4 | ___5 - 6 | ___Every day
On a day when you have had wine, sherry, or vermouth to drink, how many glasses have you been drinking?
___1 - 2 | ___3 - 4 | ___5 - 8 | ___9 - 14 | ___15 or more
AND
4c. On average how many days per week have you been drinking liquor (gin, vodka, rum, brandy, whiskey, etc.)?
___None | ___1 - 2 | ___3 - 4 | ___5 - 6 | ___Every day
On a day when you have had liquor to drink, how many single shots have you been drinking?
___1 - 2 | ___3 - 4 | ___5 - 8 | ___9 - 14 | ___15 or more
5. In the last three months have you felt you should:
a. lose some weight | | ___No | ___Sometimes | ___Quite Often | ___Very Often
b. cut down or stop smoking | | ___No | ___Sometimes | ___Quite Often | ___Very Often
c. cut down or stop drinking | | ___No | ___Sometimes | ___Quite Often | ___Very Often
d. do more to keep fit | | ___No | ___Sometimes | ___Quite Often | ___Very Often
6. In the last three months has anyone annoyed you or got on your nerves by telling you to:
a. change your weight | | ___No | ___Sometimes | ___Quite Often | ___Very Often
b. cut down or stop smoking | | ___No | ___Sometimes | ___Quite Often | ___Very Often
c. cut down or stop drinking | | ___No | ___Sometimes | ___Quite Often | ___Very Often
d. do more to keep fit | | ___No | ___Sometimes | ___Quite Often | ___Very Often
7. In the last three months, have you felt guilty or bad about:
a. your weight | | ___No | ___Sometimes | ___Quite Often | ___Very Often
b. how much you smoke | | ___No | ___Sometimes | ___Quite Often | ___Very Often
c. how much you drink | | ___No | ___Sometimes | ___Quite Often | ___Very Often
d. how unfit you are | | ___No | ___Sometimes | ___Quite Often | ___Very Often
8. In the last three months, have you been waking up wanting to:
a. exercise to keep fit | | ___No | ___Sometimes | ___Quite Often | ___Very Often
b. smoke a cigarette | | ___No | ___Sometimes | ___Quite Often | ___Very Often
c. have an alcoholic drink | | ___No | ___Sometimes | ___Quite Often | ___Very Often
d. have something to eat | | ___No | ___Sometimes | ___Quite Often | ___Very Often
9. Now that you have completed this form, do you think you currently have:
a. a weight problem | | ___Definitely | ___Probably | ___No | ___Don't Know
b. a smoking problem | | ___Definitely | ___Probably | ___No | ___Don't Know
c. a drinking problem | | ___Definitely | ___Probably | ___No | ___Don't Know
d. a fitness problem | | ___Definitely | ___Probably | ___No | ___Don't Know
10. Thinking back, would you say at any time in the past you had:
a. a weight problem | | ___Definitely | ___Probably | ___No | ___Don't Know
b. a smoking problem | | ___Definitely | ___Probably | ___No | ___Don't Know
c. a drinking problem | | ___Definitely | ___Probably | ___No | ___Don't Know
d. a fitness problem | | ___Definitely | ___Probably | ___No | ___Don't Know

### References

- Kristenson, H., and Trell, E.
- Indicators of alcohol consumption: Comparisons between a questionnaire (Mm-MAST), interviews, and serum _-glutamyl transferase (GGT) in a health survey of middle-aged males. British Journal of Addiction 77, 297-304, 1982.

- Mayfield, D.; McLeod, G.; and Hall, P.
- The CAGE questionnaire: Validation of a new alcoholism screening instrument. American Journal of Psychiatry 131:1121-1128, 1974.

- Reproduced with permission.