# Consensus Panel

Chair
- Frederic C. Blow, Ph.D.
- Assistant Professor and Assistant Research Scientist
- Department of Psychiatry
- Alcohol Research Center
- University of Michigan
- Ann Arbor, Michigan

Workgroup Leaders
- Roland M. Atkinson, M.D.
- Professor
- Head of Division of Geriatric Psychiatry
- Department of Psychiatry
- School of Medicine
- Oregon Health Sciences University
- Portland, Oregon
- James Campbell, M.D., M.S.
- Associate Professor
- Acting Chairman
- Department of Family Medicine
- Case Western Reserve University
- Medical Director
- Senior Health Recovery Resources
- Metrohealth Medical Center
- Cleveland, Ohio
- Anne M. Gurnack, Ph.D.
- Professor and Director of Assessment
- Department of Political Science
- University of Wisconsin at Parkside
- Kenosha, Wisconsin
- Jeanie L. Holt, R.N.C.
- Clinical Staff Nurse
- Heritage Home Health and Hospice
- Meredith, New Hampshire
- David Oslin, M.D.
- Assistant Professor
- Addiction and Geriatric Psychiatry
- Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Gerald D. Shulman, M.A., F.A.C.A.T.A.
- Consultant
- Winter Haven, Florida

Panelists
- Charles Bearcomesout
- Traditional Coordinator
- Traditional Component
- Northern Cheyenne Recovery Center
- Lame Deer, Montana
- Larry W. Dupree, Ph.D.
- Professor
- Department of Aging and Mental Health
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida
- Richard E. Finlayson, M.D.
- Consultant in Adult Psychiatry
- Former Medical Director of Addiction Services
- Department of Psychiatry and Psychology
- Mayo Clinic
- Associate Professor of Psychiatry
- Mayo Medical School
- Rochester, Minnesota
- Lissy F. Jarvik, M.D., Ph.D.
- Distinguished Physician (11L)
- Psychiatry Department
- West Los Angeles VA Medical Center
- Professor Emerita
- Department of Psychiatry and Biobehavioral Sciences
- University of California-Los Angeles
- Los Angeles, California
- Hila Richardson, Dr.P.H.
- Deputy Director
- Medical Research and Practice Policy
- National Center on Addiction and Substance Abuse
- Columbia University
- New York, New York
- Marguerite T. Saunders, M.S.
- Saunders Consulting Services
- Albany, New York
- Sharon L. Sheahan, Ph.D., C.F.N.P.
- Associate Professor of Nursing
- College of Nursing
- University of Kentucky
- Lexington, Kentucky
- Erma Polly Williams, M.R.E.
- Program Support Specialist
- Robert Wood Johnson Medical School
- University of Medicine and Dentistry of New Jersey
- New Brunswick, New Jersey