# Tables and Figures

Figure 1-1: Manifestations of Domestic Violence

Figure 3-1: Models for Batterers' Intervention Programs

Figure 3-2: Positive and Negative Aspects of Bonding Among Batterers

Figure 4-1: Safeguarding Important Documents

Figure 4-1: Safeguarding Important Documents

As part of the survivor's safety plan, it may be helpful to advise the survivor client to keep important documents in a safe deposit box or in a place where her partner cannot gain access to them. These materials may include some or all of the following:

- Social security documents
- Marriage license
- Passport(s)
- Copies of any protective orders or divorce or custody papers
- Green card
- Children's birth certificates
- Information about medical history, including vaccination schedules for children and records on health care visits
- Extra sets of home and car keys
- Photographic documentation of abuse
- Deeds or leases that document residence, titles to cars
- Other financial documents such as savings deposit books and payment books

Figure 4-2: Gathering Documentation

Figure 4-2: Gathering Documentation

All States have mandatory reporting laws for child abuse, but only some have or are developing such laws for reporting domestic violence. Some battered women's advocates support such laws because they "take the pressure off" the victims to report their batterers. Some domestic violence service providers also believe that it is the community's responsibility -- not the victim's -- to stop the batterer's behavior. Some States mandate the arrest of batterers whether or not their victims press charges, and some are proposing mandatory physician reporting of battering. Concerns have been raised, however, about preserving victims' ability to decide whether they want to become involved in the criminal justice system or in domestic violence programs. For this reason, such laws are opposed by some battered-women's groups, who believe they put women at greater risk.

Regardless of whether a survivor elects to pursue legal remedies, she is well-advised to document the nature and extent of the domestic violence she and her family have experienced by compiling copies of

- Criminal justice reports, including prior legal actions (e.g., restraining orders) against batterers
- Any previous CPS reports that can be obtained
- Hospital records and health history of the client

Complete criminal justice and medical records may be difficult to obtain. In the case of medical records, for example, survivors may have made visits to numerous institutions (e.g., clinics and emergency rooms) in order to avoid raising the suspicion of domestic violence. Issues of confidentiality also may be an impediment to obtaining these records. (See Appendix B for more information on confidentiality.) When clients are unsuccessful in compiling information from standard sources, their self-reports to substance abuse treatment providers, documented in their program records, can be used to fill in the gaps and to help support their claims. When entering notes into the client's record, however, it is important to include the facts as presented or observed. Records can be subpoenaed and "gratuitous comments or opinions" may be used against survivors in custody cases (Minnesota Coalition for Battered Women, 1992, p. 41).

Figure 6-1: Key Linkages

Figure 6-2: Facets of Collaboration Between Substance Abuse Treatment and Domestic Violence Programs

Figure B-1: Client Consent Form: Required Items

Figure B-2: Consent for the Release of Confidential Information

Figure B-2: Consent for the Release of Confidential Information

I, ____________________________________________________________________, authorize

(Name of client)

__________________________________________________________________________

(Name or general designation of program making disclosure)

to disclose to ___________________________________________________________

(Name of person or organization to which disclosure is to be made)

the following information: _______________________________________________

__________________________________________________________________________

__________________________________________________________________________

(Nature of the information, as limited as possible)

The purpose of the disclosure authorized herein is to: _____________________________________

________________________________________________________________________

________________________________________________________________________

(Purpose of disclosure, as specific as possible)

I understand that my records are protected under the Federal regulations governing

Confidentiality of Alcohol and Drug Abuse Client Records, 42 C.F.R. Part 2, and cannot be disclosed

without my written consent unless otherwise provided for in the regulations. I also understand that I

may revoke this consent at any time except to the extent that action has been taken in reliance on it,

and that in any event this consent expires automatically as follows:

__________________________________________________________________________

(Specification of the date, event, or condition upon which this consent expires)

Dated: _____________________________________________________________

(Signature of participant)

_________________________________________________________________

(Signature of parent, guardian, or authorized representative when required)

Figure B-3: Prohibition on Redisclosing Information Concerning Substance Abuse Treatment Clients

Figure B-3: Prohibition on Redisclosing Information Concerning Substance Abuse Treatment Clients

This notice accompanies a disclosure of information concerning a client in alcohol/drug abuse treatment, made to you with the consent of such client. This information has been disclosed to you from records protected by Federal confidentiality rules (42 C.F.R. Part 2). The Federal rules prohibit you from making any further disclosure of this information unless further disclosure is expressly permitted by the written consent of the person to whom it pertains or as otherwise permitted by 42 C.F.R. Part 2. A general authorization for the release of medical or other information is NOT sufficient for this purpose. The Federal rules restrict any use of the information to criminally investigate or prosecute any alcohol or drug abuse client.

Figure B-4: Qualified Service Organization Agreement