# Consensus Panel

Co-Chairs
- Patricia Anne Fazzone, R.N., D.N.Sc., M.P.H., C.S.
- Assistant Professor
- School of Nursing
- Kansas University Medical Center
- Kansas City, Kansas
- John Kingsley Holton, Ph.D.
- Site Director
- Maternal and Child Health
- School of Public Health
- Harvard University
- Chicago, Illinois
- Beth Glover Reed, Ph.D.
- Associate Professor
- School of Social Work and Program in Women's Studies
- University of Michigan
- Ann Arbor, Michigan

Workgroup Leaders
- Larry Bennett, Ph.D.
- Assistant Professor
- Jane Addams College of Social Work
- University of Illinois at Chicago
- Chicago, Illinois
- Vivian Brown, Ph.D.
- President and Chief Executive Officer
- PROTOTYPES
- Culver City, California
- Candace M. Shelton, M.S., C.A.D.A.C.
- Clinical Director
- Guiding Star Lodge
- Indian Rehabilitation, Inc.
- Phoenix, Arizona
- Kimberly Smith-Cofield, M.Ed.
- Executive Director
- Casa Myrna Vasquez, Inc.
- Boston, Massachusetts
- Carey Tradewell, M.S., C.A.D.C. III
- President and Chief Executive Officer
- Milwaukee Women's Center, Inc.
- Milwaukee, Wisconsin
- Oliver J. Williams, Ph.D.
- Associate Professor
- Graduate School of Social Work
- University of Minnesota
- Minneapolis, Minnesota

Panelists
- Roland Byrd, C.C.D.C., M.A.
- Counselor
- Montana Chemical Dependency Center
- Montana State Department of Public Health and Human Services
- Butte, Montana
- Lonnie Hazlewood, M.S.H.P.
- Managing Partner
- Austin Stress Clinic, Ltd.
- Austin, Texas
- Judy Howard, M.D.
- Professor of Pediatrics
- Developmental Studies Program
- Department of Pediatrics
- School of Medicine
- University of California at Los Angeles
- Los Angeles, California
- Kate Malliarakis, C.N.P., M.S.M., N.C.A.D.C. II
- American College of Nurse Practitioners
- Arlington, Virginia
- Jan Mickish, Ph.D.
- Executive Director
- Colorado Domestic Violence Coalition
- Denver, Colorado
- Brenda Miller, Ph.D.
- Deputy Director
- Research Institute on Addictions
- Buffalo, New York
- Beth E. Richie, Ph.D.
- Associate Professor
- Program in Public Health
- Hunter College
- City University of New York
- New York, New York
- Eric D. Wish, Ph.D.
- Director
- Center for Substance Abuse Research
- University of Maryland at College Park
- College Park, Maryland
- Diane Zainhofsky
- Executive Director
- Abused Adult Resource Center
- Bismarck, North Dakota