# Appendix G—Field Reviewers

- Becci Akin
- Research Assistant
- School of Social Welfare
- Twente Hall
- University of Kansas
- Lawrence, Kansas

- Judy Atkin
- High Risk Coordinator
- Providence Prenatal Center
- Holyoke, Massachusetts

- Kathleen Austin, C.D.C. III, N.C.A.C. II
- Alcohol Therapist II
- Adult Medicine/Ambulatory Care
- Harborview Medical Center
- Seattle, Washington

- Kristen Barry, Ph.D.
- Associate Research Scientist
- Health Services Reseach and Development Field Program
- Ann Arbor, Michigan

- Rosalind Brannigan
- Vice President
- Drug Strategies
- Washington, D.C.

- Donna L. Caldwell, Ph.D.
- Senior Research Associate
- National Perinatal Information Center
- Providence, Rhode Island

- Jacquelyn C. Campbell, R.N., Ph.D.
- Graduate Academic Programs
- School of Nursing
- Johns Hopkins University
- Baltimore, Maryland

- Peter J. Cohen, M.D., J.D.
- Special Expert
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Carol Colleran, C.A.P., I.C.A.D.C.
- Director
- Older Adult Services
- Hanley-Hazelden
- Hazelden Foundation
- West Palm Beach, Florida

- James Collins, Ph.D.
- Senior Program Director
- Health and Social Policy Division
- Research Triangle Institute
- Research Triangle Park, North Carolina

- Martin C. Doot, M.D.
- Chief
- Division of Addiction Medicine
- Addiction Medicine/ Family Practice
- Lutheran General Hospital Advocate
- Park Ridge, Illinois

- Joel A. Egertson
- Senior Advisor to the Director
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Jerry P. Flanzer, D.S.W.
- Director
- Recovery and Family Treatment, Inc.
- Alexandria, Virginia

- Sally Flanzer, Ph.D.
- Acting Director
- Program Policy and Planning Division
- National Center on Child Abuse and Neglect
- Children's Bureau
- Department of Health and Human Services
- Washington, D.C.

- Sandra Handley, Ph.D., R.N., C.A.R.N.
- Consultant
- Addiction Training Center
- University of Missouri-Kansas City
- Kansas City, Missouri

- Susan Hernandez
- Assessment Supervisor
- Southwest Migrant Farm Workers and Native American (TIGUA) Assistance Program
- West Texas Council on Alcoholism and Drug Abuse
- El Paso, Texas

- Flo Hilliard, M.H.S.
- Community Outreach Specialist
- Rural South Central Wisconsin Perinatal
- Substance Abuse Project
- Health and Human Issues
- University of Wisconsin
- Madison, Wisconsin

- Lt. Col. Kenneth J. Hoffman, M.D., M.P.H., M.C.F.S.
- Director, Center for Addiction Medicine
- Center for Training and Education in Addiction Medicine (C-Team)
- Department of Preventive Medicine/Biometrics
- Uniformed Services University of the Health Sciences
- Bethesda, Maryland

- Nancy Holmberg, M.S.
- Licensing Specialist
- Division of Children and Family Services
- Wisconsin Department of Health and Family Services
- Madison, Wisconsin

- The Honorable Peggy Fulton Hora
- Judge
- County of Alameda
- Municipal Court of California
- Hayward, California

- Frank J. Jans, M.A., C.C.S.
- Manager of Outpatient Psychiatry
- Department of Psychiatry
- Allegheny General Hospital
- Pittsburgh, Pennsylvania

- Denise Johnson, M.S.
- Team Leader
- Family and Intimate Violence Prevention Team
- Division of Violence Prevention
- National Center for Injury Prevention and Control
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Gerald A. Juhnke, Ed.D., L.P.C., N.C.C., M.A.C.
- Assistant Professor
- Department of Counseling and Educational Development
- University of North Carolina at Greensboro
- Greensboro, North Carolina

- Dennis Kennedy
- PAVE
- Denver, Colorado

- Joan Kub, Ph.D., R.N.
- Assistant Professor
- School of Nursing
- Johns Hopkins University
- Baltimore, Maryland

- Jeffrey N. Kushner
- Drug Court Administrator
- 22nd Judicial District
- Municipal Court of Saint Louis
- Saint Louis, Missouri

- Mary Jane Landry
- Executive Director
- Alcohol and Other Drug Council of Kenosha County Inc.
- Kenosha, Wisconsin

- Sandra C. Lapham, M.D.
- Director
- Substance Abuse Research Programs
- Lovelace Institutes
- Institute for Health and Population Research
- Albuquerque, New Mexico

- Kenneth E. Leonard, Ph.D.
- Senior Research Scientist
- Research Institute on Addictions
- Buffalo, New York

- Judith Levy, Ph.D.
- Associate Professor
- School of Public Health
- University of Illinois
- Chicago, Illinois

- Jane M. Liebshutz, M.D.
- Clinical Instructor of Medicine
- Section of General Internal Medicine
- Boston City Hospital
- Boston University School of Medicine
- Boston, Massachusetts

- Sheila P. Litzky, M.A.
- Statewide Coordinator for Women's Services
- Alcohol and Drug Abuse Administration
- Baltimore, Maryland

- N. Ann Lowrance, M.S.
- Deputy Commissioner
- Victim Services
- Oklahoma Department of Mental Health and Substance Abuse Services
- Oklahoma City, Oklahoma

- Colleen R. McLaughlin, Ph.D.
- Research Analyst
- Substance Abuse Unit
- Virginia Department of Juvenile Justice
- Richmond, Virginia

- Cassandra Newkirk, M.D.
- Deputy Commissioner of Offender Services
- Department of Corrections
- Atlanta, Georgia

- Virginia O'Keeffe, C.C.D.C. III, O.P.S.
- Executive Director
- Amethyst, Inc.
- Columbus, Ohio

- Christine D. Olson, M.S.
- Director
- Services for Families, Women, and Children
- Colorado Alcohol and Drug Abuse Division
- Denver, Colorado

- Paula Ortiz Smith, L.M.S.W.
- Social Services Coordinator
- Ben Archer Health Center
- Hatch, New Mexico

- Gennaro Ottomanelli, Ph.D.
- Director
- Division of Drug Dependence
- Kings County Addictive Disease Hospital
- Brooklyn, New York

- Pat Paluzzi, C.N.M., M.P.H.
- Senior Technical Advisor
- Special Projects Section
- American College of Nurse-Midwives
- Washington, D.C.

- Carolyn Peake
- Program Manager
- National Institute of Justice
- Washington, D.C.

- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center
- Los Angeles, California

- Charles Ray
- Executive Director
- National Community Mental Healthcare Council
- Rockville, Maryland

- Geri M. Redden, M.Ed.
- Executive Director
- Educational Center on Family Violence
- St. Louis, Missouri

- Hila Richardson, Dr.P.H.
- Deputy Director
- Medical Research and Practice Policy
- National Center on Addiction and Substance Abuse
- Columbia University
- New York, New York

- Josie T. Romero, M.S.W., L.C.S.W.
- Executive Director
- Hispanic Institute for Family Development
- San Jose, California

- Gwen Rubinstein
- Deputy Director of National Policy
- Legal Action Center
- Washington, D.C.

- Eleanor Sargent
- Director
- Clinical Issues
- The National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Gerald Silverman
- Senior Policy Analyst
- U.S. Department of Health and Human Services
- Office of the Assistant Secretary for Planning and Evaluation
- Washington, D.C.

- Richard T. Suchinsky, M.D.
- Associate Director
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Sue Thau
- Community Anti-Drug Coalitions of America (CADCA)
- Washington, D.C.

- Daphne Walker-Thoth, M.Ed.
- Project Manager
- St. Louis Target Cities Project
- Missouri Division of Alcohol and Drug Abuse
- Missouri Department of Mental Health
- Saint Louis, Missouri

- Shirley Whitney
- Director
- Preventive Services Development
- Administration of Children Services
- New York, New York

- Theresa M. Zubretsky
- Director
- Human Services Policy and Planning
- New York State Office for the Prevention of Domestic Violence
- Rensselaer, New York