# Appendix F—Resource Panel

- Marilyn Benoit, M.D.
- American Academy of Child and Adolescent Psychiatry
- Washington, D.C.

- Ruth H. Carlsen Kahn, D.N.Sc.
- Health Manpower Specialist
- Bureau of Health Professionals
- Division of Medicine
- Health Resources and Services Administration
- Rockville, Maryland

- Johanna Clevenger, M.D.
- Chief
- Alcoholism and Substance Abuse Program Branch
- Indian Health Service
- Rockville, Maryland

- Joel A. Egertson
- Senior Advisor to the Director
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Jennifer Fiedelholtz
- Associate Administrator
- Office for Women's Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Sally Flanzer, Ph.D.
- Acting Director
- Program Policy and Planning Division
- National Center on Child Abuse and Neglect
- Children's Bureau
- Department of Health and Human Services
- Washington, D.C.

- Janet S. Hartnett
- Deputy Director
- Office of Planning, Research, and Evaluation
- Administration for Children and Families
- Department of Health and Human Services
- Washington, D.C.

- Gil Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Denise Johnson, M.S.
- Team Leader
- Family and Intimate Violence Prevention Team
- Division of Violence Prevention
- National Center for Injury Prevention and Control
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Pat Paluzzi, C.N.M., M.P.H.
- Senior Technical Advisor
- Special Projects Section
- American College of Nurse-Midwives
- Washington, D.C.

- Carolyn Peake
- Program Manager
- National Institute of Justice
- Washington, D.C.

- Gwen Rubinstein
- Deputy Director of National Policy
- Legal Action Center
- Washington, D.C.

- Jolene Sanders
- Program Specialist
- Quality Assurance Programs
- National Association of State Alcohol and Drug Abuse Directors, Inc.
- Washington, D.C.

- Irene Sandvold, Dr.P.H., C.N.M.
- Nurse Consultant
- Division of Nursing
- Health Resources and Services Administration
- Department of Health and Human Services
- Rockville, Maryland

- Eleanor Sargent
- Director
- Clinical Issues
- The National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Richard T. Suchinsky, M.D.
- Associate Director
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- Mary Randolf Turner
- Public Relations Specialist
- American Academy of Child and Adolescent Psychiatry
- Washington, D.C.