# Appendix E—Hotlines and Other Resources For Domestic Violence and Related Issues

This appendix provides addresses, phone numbers, and information on three types of domestic violence organizations and groups in related fields such as rape, child abuse and neglect, and victimization. Hotlines provide crisis counseling and referrals to victims and those in crisis and usually supply general information either by mail or over the phone. General resources send bulletins, pamphlets, manuals, and other publications by mail (sometimes at cost); sometimes they give information over the phone. They also may provide additional services, such as referrals. Most of them serve the general public, although some target professionals in specific fields. The other services category includes research and policy groups and those that provide technical assistance, training, and advocacy. Unlike those in the previous category, other services tend to target professionals in specific fields, as indicated, and are not resources for the general public. Many of the programs and organizations listed below provide more than one type of service, so they are categorized by their primary purpose.

## Hotlines

### National Domestic Violence Hotline

- (800) 799-SAFE
- (800) 787-3224 (TDD)
- Suite 101-297
- 3616 Far West Boulevard
- Austin, TX 78731-3074

The National Domestic Violence Hotline links individuals and services using a nationwide database of domestic violence and other emergency shelters, legal advocacy and assistance programs, and social services programs. The hotline provides crisis intervention, information about sources of assistance, and referrals to battered women's shelters.

### Rape, Abuse, and Incest National Network (RAINN)

- (800) 656-4673

RAINN links 628 rape crisis centers nationwide. Sexual assault survivors who call will be automatically connected to a trained counselor at the closest center in their area.

### Childhelp USA/National Child Abuse Hotline

- (800) 4A-CHILD
- 15757 North 78th Street
- Scottsdale, AZ 85260
- (602) 922-8212

With a focus on children and the prevention of child abuse, this hotline provides crisis counseling, referrals, and reporting guidance to callers in crisis, including children, troubled parents, and adult survivors of abuse. All calls are answered by a staff of professional counselors. In addition, statistical and other informative materials can be ordered through this number. Access to information on partner violence is limited.

Childhelp, one of the largest national, nonprofit child abuse treatment and prevention agencies in the country, also runs the nation's first residential treatment facility for abused children, provides prevention services and training, and participates in advocacy and education efforts.

## General Resources

### American College of Obstetricians and Gynecologists (ACOG)

- ACOG Resource Center
- 409 12th Street, S.W.
- Washington, DC 20024-2188
- (202) 638-5577

ACOG has patient education pamphlets and bulletins for medical professionals on both domestic violence and substance abuse.

### American Medical Association (AMA)

- Department of Mental Health
- 515 State Street
- Chicago, IL 60610
- Contact: Jean Owens
- (312) 464-5000
- (312) 464-5066 (to order resources)
- (312) 464-4184 (fax)

The AMA educates physicians through publications, conferences, and by serving as a resource center for physicians and other concerned professionals. Among its publications are six diagnostic and treatment guidelines on child physical abuse and neglect, child sexual abuse, domestic violence, elder abuse and neglect, mental health effects of domestic violence, treatment and prevention of sexual assault, and media violence.

### March of Dimes Birth Defects Foundation

- 1275 Mamaroneck Avenue
- White Plains, NY 10605
- Attn: Resource Center
- (914) 428-7100
- http://www.modimes.org

The March of Dimes provides general information on prenatal care and on the first few years of life through its resource center and its fulfillment center. The March of Dimes does not have a hotline.

- March of Dimes Resource Center
- (888) 663-4637
- (914) 997-4763 (fax)
- resourcecenter@modimes.org
- Contact: Beverly Robertson, Director

Callers to this number can speak to someone about pregnancy, prepregnancy, drug use during pregnancy, birth defects, genetics, and other issues related to prenatal care.

- March of Dimes Fulfillment Center
- (800) 367-6630

Callers to this number can only place an order for materials. Two domestic violence materials are available at cost: Abuse During Pregnancy Nursing Module, which provides continuing education units to nurses, and a video titled Crime Against the Future.

### National Center for Missing or Exploited Children (NCMEC)

- Suite 550
- 2101 Wilson Boulevard
- Arlington, VA 22201-3052
- Hotline: (800) THE LOST, (800) 843-5678, (800) 826-7653 (TDD)
- Business office: (703) 235-3900, (703) 235-4067 (fax)
- http://www.missingkids.org

NCMEC leads national efforts to locate and recover missing children and raises public awareness about ways to prevent child abduction, molestation, and sexual exploitation. The hotline is available to report information on missing or exploited children or to request information or assistance. NCMEC publishes materials, including handbooks, pamphlets containing parental and professional guidelines on runaways and missing or exploited children, and publication packages aimed toward families, child care and social service practitioners, and law enforcement, legal, and criminal justice professionals.

### National Clearinghouse on Child Abuse and Neglect

- P.O. Box 1182
- Washington, DC 20013-1182
- (800) FYI-3366
- (703) 385-7565
- (703) 385-3206 (fax)
- nccanch@calib.com

This clearinghouse offers child abuse and neglect information in the form of manuals, research reports, studies, directories, grant compendia, literature reviews, annotated bibliographies, fact sheets, database searches, CD ROM databases, and on-line services. It is sponsored by the National Center on Child Abuse and Neglect.

### National Coalition Against Domestic Violence

- P.O. Box 18749
- Denver, CO 80218
- (303) 839-1852
- (303) 831-9251 (fax)

The National Coalition Against Domestic Violence serves as an information and referral center for the general public, the media, battered women and their children, and agencies and organizations. Among its purposes are to enhance coalition-building at the local, State, and national levels; support the provision of community-based, nonviolent alternatives such as safe homes and shelters for battered women and their children; provide information and referral services, public education, and technical assistance; and develop public policy and innovative legislation. The coalition maintains a public policy office in Washington, DC, and maintains a National Directory of Domestic Violence Programs.

### National Sheriffs 'Association

- 1450 Duke Street
- Alexandria, VA 22314
- (800) 424-7827
- (703) 836-7827

The National Sheriffs' Association has developed a handbook on victim's assistance for law enforcement officers who deal with all types of victims, including those of domestic violence. It provides training in dealing with victims sensitively, finding resources in one's community to help them, and setting up a victim assistance program.

### National Victim Center (NVC)/INFOLINK

- (800) FYI-CALL
- (703) 276-2880
- www.nvc.org

NVC operates an information and referral program called INFOLINK, which provides a toll-free source of comprehensive crime and victim-related information as well as referrals to over 8,000 victim assistance programs across the nation. Each caller can receive up to 5 of the 70 information bulletins free of charge. In addition, all INFOLINK bulletins, as well as other important information, are available on NVC's website.

## Other Services

### Center for the Prevention of Sexual and Domestic Violence

- Suite 200
- 936 North 34th Street
- Seattle, WA 98103
- (206) 634-1903
- (206) 634-0115 (fax)
- cpsdv@cpsdv.seanet.com
- http://www.cpsdv.org

The Center for the Prevention of Sexual and Domestic Violence is the only national organization working with and within religious communities on issues of sexual and domestic violence. Although the center's constituency includes those in the fields of law, health care, social services, counseling, and other fields, the center primarily targets religious professionals and teaches them how to effectively respond to and prevent sexual abuse and domestic violence. Services and products include trainings, workshops, and seminars; consultations; videos; specialized curriculum materials; and publications.

### Colorado Coalition Against Domestic Violence

- P.O. Box 18902
- Denver, CO 80218
- (303) 831-9632

This group does public policy work and provides community education and training, information in the form of statistics and brochures, and technical assistance to domestic violence programs.

### Domestic Violence Project/Face-to-Face

- (800) 842-4546

This project, sponsored by the American Academy of Facial Plastic and Reconstructive Surgery, offers free facial reconstructive surgery to anyone who has been physically disfigured due to domestic violence.

### Domestic Violence Training Project (DVTP)

- 900 State Street
- New Haven, CT 06511
- (203) 865-3699

DVTP, a project for health professionals, runs enhanced education, early intervention, and advocacy programs to end domestic violence. Ongoing programs and services include seminars, conferences, consultation services, and case reviews. Project SAFE (Safety Assessment for Everyone) is an education campaign to raise health care professionals' awareness of domestic violence as a significant health problem and increase their collaboration with community-based domestic violence advocates.

### Family Violence and Sexual Assault Institute

- Suite 130
- 1121 ESE Loop 323
- Tyler, TX 75701
- (903) 534-5100
- (903) 534-5454 (fax)
- fvsai@e-tex.com

To improve networking among researchers, practitioners, and agencies, the Family Violence and Sexual Assault Institute maintains an international clearinghouse, reviews its materials, and disseminates the information through its Family Violence and Sexual Assault Bulletin. This independent, nonprofit corporation helps crisis centers, agencies, universities, and counseling clinics develop treatment programs for partner and sexual abuse and has published several books and bibliographies as a result of this research. The institute also provides training and consultation in the form of program evaluation, research, and technical assistance.

- National Center on Elder Abuse (NCEA)
- Suite 500
- 810 First Street, N.E.
- Washington, DC 20002-4267
- (202) 682-2470
- (202) 289-6555 (fax)

NCEA performs clearinghouse functions, develops and disseminates information, provides training and technical assistance, and conducts research and demonstration projects of national significance. In addition, NCEA runs the country's only automated, elder abuse literature search and retrieval system. Four organizations comprise the NCEA: the American Public Welfare Association, the National Association of State Units on Aging, the University of Delaware College of Human Resources, and the National Committee for Prevention of Elder Abuse.

### National Clearinghouse on Marital and Date Rape

- http://members.aol.com/ncmdr/index.html

The National Clearinghouse on Marital and Date Rape provides fee-based phone consultations for information, referrals, strategies, and advocacy. The website contains fee and membership information.

### National Criminal Justice Reference Service (NCJRS)

- P.O. Box 6000
- Rockville, MD 20847-6000
- (800) 851-3420
- (301) 251-5500
- http://www.ncjrs.org
- askncjrs@ncjrs.org

NCJRS, one of the most extensive sources of information on criminal and juvenile justice in the world, provides services to an international community of policymakers and professionals. NCJRS is a collection of clearinghouses supporting all bureaus of the U.S. Department of Justice, Office of Justice Programs. It also supports the Office of National Drug Control Policy. Information is available through information specialists, on-line services, or its CD ROM database. NCJRS does not provide counseling or legal advice.

### National Network to End Domestic Violence

- Suite 900
- 701 Pennsylvania Avenue, N.W.
- Washington, DC 20004
- (202) 347-9520

A member organization of State domestic violence coalitions, the National Network to End Domestic Violence supports 2,000 programs and services, provides training, and focuses on public policy issues.

### The Domestic Violence Resource Network

The Domestic Violence Resource Network comprises four entities: the Resource Center on Domestic Violence: Child Protection and Custody; the National Resource Center on Domestic Violence; the Health Resource Center on Domestic Violence; and the Battered Women's Justice Project (a collaboration of three organizations).

#### Resource Center on Domestic Violence: Child Protection and Custody

- Project of the National Council of Juvenile and Family Court Judges (NCJFCJ) Violence Project
- P.O. Box 8970
- Reno, NV 89507
- (800) 527-3223
- (702) 784-6160 (fax)

NCJFCJ, a national judicial membership organization, runs the Family Violence Project with the goal of developing, testing, and promoting criminal, civil, and family court procedures that better respond to domestic violence. The Resource Center, a component of the Family Violence Project, provides immediate access to information and training for judges, court workers, advocates, lawyers, child protective workers, law enforcement personnel, and other professionals dealing with child protection/custody issues in the context of domestic violence. Callers can receive accurate, up-to-date information and technical assistance over the phone or can request information packets, program materials, and other resources.

The Family Violence Project developed -- through a committee of domestic violence experts including judges, attorneys, battered women's advocates, health care professionals, and law enforcement personnel -- the Model State Code on Domestic and Family Violence. The project provides technical assistance to implement the model code.

#### National Resource Center on Domestic Violence

- Project of the Pennsylvania Coalition Against Domestic Violence
- Suite 1300
- 6400 Flank Drive
- Harrisburg, PA 17112
- (800) 537-2238
- (717) 545-9456 (fax)

The National Resource Center on Domestic Violence (NRC), operated by the Pennsylvania Coalition Against Domestic Violence, is a source of comprehensive information, training, and technical assistance on domestic violence prevention and intervention. NRC serves as a central resource for the collection, preparation, analysis, and dissemination of information on domestic violence; identifies and supports the development of innovative and exemplary intervention and prevention resources; and maintains a comprehensive database of information to coordinate resource development and technical assistance throughout the nation. Although its target groups are domestic violence programs and State coalitions, NRC also serves government agencies, policy leaders, media, and other professionals and organizations involved in the prevention or response to domestic violence.

#### Health Resource Center on Domestic Violence

- Project of the Family Violence Prevention Fund
- Suite 304
- 383 Rhode Island Street
- San Francisco, CA 94103-5133
- toll free (888) Rx ABUSE, weekdays 9 a.m. to 5 p.m., P.S.T.
- (415) 252-8991 (fax)
- http://www.fvpf.org/health/

The Health Resource Center, which focuses on strengthening the health care response to domestic violence, provides resources and training materials, technical assistance, and information and referrals to health care professionals and others who help victims of domestic violence. Its products and services include comprehensive resource manuals providing the tools for an effective multidisciplinary response; multidisciplinary protocols emphasizing routine screening and identification of domestic violence; assistance with health care training programs and protocol development; models for local, State, and national health policymaking; a national network of experts for public speaking, training, and consultation; and educational materials specifically developed for health care providers.

#### Battered Women's Justice Project (BWJP)

- 4032 Chicago Avenue, South
- Minneapolis, MN 55407
- 903-0111
- (612) 824-8965 (fax)

The BWJP serves as a resource center and national toll-free information line regarding domestic violence issues in the criminal and civil justice systems. A collaboration of three organizations, the BWJP responds to specific requests for information or technical assistance from people who work with battered women. Each component specializes in certain areas of law and responds to questions about training, practices, and policies in those areas. BWJP develops resources such as bibliographies, various resource packets, and information about model programs, protocols, curricula, experts in the field, and training materials. The project is funded by a grant from the U.S. Department of Health and Human Services. The three organizations can be reached through the same toll-free number listed above; each has its own extension.

##### Extension 1:

The Criminal Justice Center -- Domestic Abuse Intervention Project: for information about criminal justice responses to domestic violence.

The Criminal Justice Center responds to questions on the criminal justice system, including law enforcement, prosecution, sentencing, probation, batterer's counseling programs, coordinated community/court responses, and victim advocacy. This office also handles information requests about domestic violence and the military and intervention strategies within Native American communities.

- 4032 Chicago Avenue, South
- Minneapolis, MN 55407
- (612) 824-8768
- (612) 824-8965 (fax)

##### Extension 2:

Civil Access and Representation Center -- Pennsylvania Coalition Against Domestic Violence: For information about civil court access and legal representation issues of battered women.

The Civil Access and Legal Center aims to enhance justice for battered women and their children by increasing their access to civil court options and legal representation. With special expertise in state-of-the-art legal approaches and model protocols, legal staff provide assistance to advocates, attorneys, court personnel, and policymakers.

- Suite 1300
- 6400 Flank Drive
- Harrisburg, PA 17112
- (717) 545-6400
- (717) 545-9456 (fax)

##### Extension 3:

The Self-Defense Center -- National Clearinghouse for the Defense of Battered Women: For information about issues that arise when battered women are charged with crimes.

The Self-Defense Center provides technical assistance to battered women charged with crimes and to their defense teams: attorneys, battered women's advocates, and expert witnesses; works with incarcerated battered women filing appeals or applying for parole or clemency; coordinates a national network of advocates and other professionals assisting battered women defendants; maintains a resource library of relevant articles and case law; and conducts community and professional training seminars.

- Suite 302
- 125 South 9th Street
- Philadelphia, PA 19107
- (215) 351-0010
- (215) 351-0779 (fax)