# Appendix A -- Bibliography

Adams, D. Treatment models of men who batter: A profeminist analysis. In: Yllo, K., and Bograd, M., eds. Feminist Perspectives on Wife Abuse. Newbury Park, CA: Sage Press, 1988.
Ageton, S.S. Sexual Assault Among Adolescents. Lexington, MA: Lexington Books. 1983.
Amaro, H.; Fried, L.E.; Cabral, H.; and Zuckerman, B. Violence during pregnancy and substance abuse. American Journal of Public Health. 1990.;80(5):575-579. [pmid: 2327535].
American Medical Association. AMA diagnostic and treatment guidelines on domestic violence. Archives of Family Medicine. 1992.;1:39-47. [pmid: 1341587].
American Medical Association, Council on Scientific Affairs. Violence Against Women: Relevance for Medical Practitioners. Chicago: American Medical Association. 1993.
American Medical Association. Diagnostic and Treatment Guidelines on Domestic Violence. Chicago: American Medical Association. 1994.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, 4th ed. Washington, DC: American Psychiatric Association, 1994.
Aramburu, B., and Leigh, B. For better or worse: Attributions about drunken aggression toward male and female victims. Violence and Victims. 1991.;6(1):31-42. [pmid: 1859805].
Arroyo, W., and Eth, S. Assessment following violence-witnessing trauma. In: Peled, E.; Jaffe, P.G.; and Edleson, J.L., eds. Ending the Cycle of Violence: Community Responses to Children of Battered Women. Newbury Park, CA: Sage Press, 1995. pp. 36-49.
Beckman, L.J., and Amaro, H. Personal and social difficulties faced by women and men entering alcoholism treatment. Journal of Studies on Alcohol. 1986.;47:135-145. [pmid: 3713175].
Beebe, D.K. Emergency management of the adult female rape victim. American Family Physician. 1991.;43:2041-2046. [pmid: 2042547].
Bell, C. Exposure to violence distresses children and may lead to their becoming violent. Psychiatric News. 1995.;6:6-8.
Bennett, L.W. Substance abuse and the domestic assault of women. Social Work. 1995.;40(6):760-772. [pmid: 8629042].
Bennett, L., and Lawson, M. Barriers to cooperation between domestic violence and substance-abuse programs. Families in Society. 1994.;75:277-286.
Bennett, L.; Tolman, R.; Rogalski, C.; and Srinivasaraghavan, J. Domestic abuse by male alcohol and drug addicts. Violence and Victims. 1994.;9(4):359-368. [pmid: 7577762].
Bergman, B., and Brismar, B. Characteristics of imprisoned wife-beaters. Forensic Science International. 1994.;65:157-167. [pmid: 8039773].
Black, C.; Buckley Bucky, S.F.; and Wilder-Padilla, S. Interpersonal and emotional consequences of being an adult child of an alcoholic. International Journal of the Addictions. 1986.;21:213-231. [pmid: 3710647].
Bland P.J., with Taylor-Smith, D. Domestic violence and addiction in women's lives. In: New York State Office for Prevention of Domestic Violence. Domestic Violence: The Alcohol and Other Drug Connection. Rensselaer, NY: New York State Office for Prevention of Domestic Violence, 1995. pp. 59-61.
Bograd, M. Feminist perspectives on wife abuse: An introduction. In: Yllo, K., and Bograd, M., eds. Feminist Perspectives on Wife Abuse. Newbury Park, CA: Sage Press, 1988. pp. 11-26.
Bowker, L.H.; Arbitall, M.; and McFerron, J.R. On the relationship between wife beating and child abuse. In: Yllo, K., and Bograd, M., eds. Feminist Perspectives on Wife Abuse. Newbury Park, CA: Sage Press, 1988. pp. 158-174.
Briere, J. Therapy for Adults Molested as Children: Beyond Survival. New York: Springer. 1989.
Brody, S.L. Violence associated with acute cocaine use in patients admitted to a medical emergency department. In: De La Rosa, M.; Lambert, E.Y.; and Gropper, B., eds. Drugs and Violence: Causes, Correlates, and Consequences. NIDA Research Monograph Series, Number 103. DHHS Pub. No. (ADM) 90-1721. Rockville, MD: National Institute on Drug Abuse, 1990. pp. 44-59.
Browne, A. Violence against women by male partners: Prevalance, outcomes, and policy implications. American Psychologist. 1993.;48(10):1077-1087. [pmid: 8256881].
Browne, A., and Finkelhor, D. The impact of child sexual abuse: A review of the research. Psychological Bulletin. 1986;99:66-77. [pmid: 3704036].
Bullock, L.; McFarlane, J.; Bateman, L.; and Miller, V. The prevalence and characteristics of battered women in a primary care setting. Nurse Practitioner. 1989.;14(6):47-55.
Bureau of Justice Statistics. Violence Between Intimates: Domestic Violence. NCJ Pub. No. NCJ-149259. Washington, DC: Bureau of Justice Statistics. 1994.
Bureau of Justice Statistics. Violence Against Women: Estimates From the Redesigned Survey. By Bachman, R., and Saltzman, L.E. NCJ Pub. No. NCJ-154348. Washington, DC: Bureau of Justice Statistics, August. 1995.
Burkins, M. Informational Packet on Individualized Care. Massillon, OH: Longford Health Source at Massillon Community Hospital. 1995.
Campbell, J. Assessing Dangerousness: Potential for Further Violence of Sexual Offenders, Batterers, and Child Abusers. Newbury Park, CA: Sage Press. 1995.
Casanave, N., and Zahn, M. "Women, murder, and male domination: Police reports of domestic homicide in Chicago and Philadelphia." Paper presented at the American Society of Criminology Annual Meeting, Atlanta, GA, October. 1986.
Cayouette, S. The Addicted or Alcoholic Batterer. Boston: EMERGE. 1990.
Chalk, R., ed. Violence and the American Family: Report of a Workshop. Washington, DC: National Academy Press. 1994.
Children's Safety Network. Domestic Violence: A Directory of Protocols for Health Care Providers. Newton, MA: Education Development Center, Inc. 1992.
Clark, S.J.; Burt, M.R.; Schulte, M.M.; and Maguire, K. Coordinated Community Responses to Domestic Violence in Six Communities: Beyond the Justice System. Washington, DC: The Urban Institute. 1996.
Coleman, D.H., and Straus, M.A. Alcohol abuse and family violence. In: Gotheil, E.; Druley, K.A.; Skoloda, T.K.; and Waxman, H.M., eds. Alcohol, Drug Abuse, and Aggression. Springfield, IL: Charles C Thomas, 1983. pp. 104-124.
Collins, B. Reconstructing codependency: Using Self-in-Relation Theory: A feminist perspective. Social Work. 1993.;38(4):470-476. [pmid: 8362280].
Collins, J.J.; Kroutil, L.A.; Roland, E.J.; and Moore-Gurrera, M. Issues in the linkage of alcohol and domestic violence services. In: Galanter, M., ed. Recent Developments in Alcoholism. Vol. 13, Alcoholism and Violence. New York: Plenum, 1997. pp. 387-405.
Collins, J.J., and Messerschmidt, P.M. Epidemiology of alcohol-related violence. Alcohol Health and Research World. 1993.;17:93-100.
Conte, J.R., and Berliner, L. The impact of sexual abuse on children: Empirical findings. In: Walker, L.E.A., ed. Handbook on Sexual Abuse of Children. New York: Springer, 1988. pp. 72-93.
Corey Handy, T.; Nichols, G.R.; and Buchino, J.J. A pediatric forensic medicine program. In: Dimmick, J.E., and Singer, D.B., eds. Perspectives in Pediatric Pathology. Vol. 19, Forensic Aspects in Pediatric Pathology. Farmington, CT: Karger, 1995. pp. 87-95.
Corey Handy, T.; Nichols, G.R.; and Smock, W.S. Repeat visitors to a pediatric forensic medicine program. Journal of Forensic Sciences. 1996.;41:841-844. [pmid: 8789843].
Covington, S.S., and Kohen, J. Women, alcohol, and sexuality. Advances in Substance Abuse. 1984.;4(1):41-56.
Craine, L.S.; Henson, C.E.; Colliver, J.A.; and MacLean, D.G. Prevalence of a history of sexual abuse among female psychiatric patients in a state hospital system. Hospital and Community. 1988.;3(39):300-304.
Crewdson, J. By Silence Betrayed: Sexual Abuse of Children in America. New York: Harper & Row. 1989.
Cronkite, R.C., and Moos, R.H. Sex and marital status in relation to treatment and outcome of alcoholic patients. Sex Roles. 1984.;11:93-112.
Cross, T.L.; Bazron, D.J.; Dennis, K.W.; and Issacs, M.R. Toward a Culturally Competent System of Care: A Monograph on Effective Services for Minority Children Who Are Severely Emotionally Disturbed. Washington, DC: CASSP Technical Assistance Center, Georgetown University Child Development Center. 1989.
Dekalb Medical Center. "Intervention strategies for identifying and treating battered women." Paper presented at a meeting at Dekalb Medical Center, Atlanta, GA, March. 1993.
Dembo, R.; Dertke, M.; LaVoie, L.; Borders, S.; Washburn, M.; and Schmeidler, J. Physical abuse, sexual victimization, and illicit drug use: A structural analysis among high risk adolescents. Journal of Adolescence. 1987.;10:13-33. [pmid: 3584593].
Douglas, M.A. The battered woman syndrome. In: Sonkin, D.J., ed. Domestic Violence on Trial: Psychological and Legal Dimensions of Family Violence. New York: Springer, 1987. pp. 39-54.
Downs, W.R.; Miller, B.A.; and Patek, D.D. Differential patterns of partner-to-woman violence: A comparison of samples of community, alcohol-abusing, and battered women. Journal of Family Violence. 1993.;8(2):113-134.
Dutton, D.G. The Domestic Assault of Women: Psychological and Criminal Justice Perspective. Boston: Allyn & Bacon. 1988.
Dutton, D.G. Theoretical and empirical perspectives on the etiology and prevention of wife assault. In: Peters, R.D.; McMahon, R.L.; and Quinsey, V.L., eds. Aggression and Violence Throughout the Lifespan. Newbury Park, CA: Sage Publications, 1992. pp. 192-221.
Dutton, D.G., with Golant, S.K. The Batterer: A Psychological Profile. New York: Basic Books. 1995.
Dutton, D.G., and Browning, J.J. Concern for power, fear of intimacy, and adverse stimuli for wife abuse. In: Hotaling, G.T.; Finkelhor, D.; Kilpatric, J.T.; and Straus, M., eds. New Directions in Family Violence Research. Newbury Park, CA: Sage Publications, 1988. pp. 163-175.
Dutton-Douglas, M.A., and Dionne, D. Counseling and shelter services for battered women. In: Steinman, M., ed. Woman Battering: Policy Responses. Cincinnati, OH: Anderson, 1991.
Edleson, J.L., and Syers, M. The relative effectiveness of group treatments for men who batter. Social Work Research and Abstracts. 1990.;26:10-17.
Edleson, J.L., and Syers, M. The effects of group treatment for men who batter: An 18-month followup study. Research in Social Work Practice. 1991.;1:227-243.
Egeland, B.; Jacobvitz, D.; and Sroufe, L.A. Breaking the cycle of abuse. Child Development. 1988.;59:1080-1088. [pmid: 3168615].
EMERGE. Guidelines for talking to abusive husbands. In: New York State Office for Prevention of Domestic Violence. Domestic Violence: The Alcohol and Other Drug Connection. Rensselaer, NY: New York State Office for Prevention of Domestic Violence, 1995. pp. 160-162.
Engelmann, J. Domestic violence, substance abuse are separate problems. Hazelden News and Professional Update May: 6-8, 1992.
Fagan, J. The Criminalization of Domestic Violence: Promise and Limits. Washington, DC: National Institute of Justice. 1996.
Faller, K.C. Child Sexual Abuse: An Interdisciplinary Manual for Diagnosis, Case Management, and Treatment. New York: Columbia University Press. 1988.
Farrell, G. Preventing repeat victimization. In: Tonry, M., and Farrington, D., eds. Crime and Justice: A Review of Research. Vol. 19, Building a Safer Society: Strategic Approaches to Crime Prevention. Chicago: University of Chicago Press, 1995.
Federal Bureau of Investigation. Crime in the United States, 1977-92. Washington, DC: Federal Bureau of Investigation. 1992.
Feldhaus, K.M.; Koziol-McLain, J.; Amsbury, H.L.; Norton, I.M.; Lowenstein, S.R.; and Abbott, J.T. Three Accuracy of 3 brief screening questions for detecting partner violence in the emergency department. Journal of the American Medical Association. 1997.;277(17):1357-1361. [pmid: 9134940].
Flanzer, J.P. Alcohol and family violence: Then to now—who owns the problem. In: Potter-Efron, R.T., and Potter-Efron, P.S., eds. . Aggression, Family Violence and Chemical Dependency: A Special Issue of the Journal of Chemical Dependency Treatment. 1990.;3(1):61-79.
Flanzer, J.P. Alcohol and other drugs are key causal agents of violence. In: Gelles, R.J., and Loseke, D.R., eds. Current Controversies on Family Violence. Newbury Park, CA: Sage Publications, 1993. pp. 171-181.
Follingstad, D.R.; Brennan, A.F.; Hause, E.S.; Polek, D.S.; and Rutledge, L.L. Factors moderating physical and psychological symptoms of battered women. Journal of Family Violence. 1991.;6(1):81-95.
Fullilove, M.T.; Fullilove, R.E.; Smith, M.; Winkler, K.; Michael, C.; Panzer, P.G.; and Wallace, R. Violence, trauma, post-traumatic stress disorder among women drug users. Journal of Traumatic Stress. 1993.;6(4):533-543.
Gelles, R., and Cornell, C.P. Intimate Violence in Families. Newbury Park, CA: Sage Press. 1990.
Gelles, R.J., and Straus, M. Intimate Violence. New York: Simon & Schuster. 1988.
Goffman, J. Batterers Anonymous: Self-Help Counseling for Men Who Batter. San Bernardino, CA: B.A. Press. 1984.
Gondolf, E.W. Who are those guys? Toward a behavioral typology of batterers. Violence and Victims. 1988.;3:187-203. [pmid: 3154179].
Gondolf, E.W. Alcohol abuse, wife assault, and power needs. Social Service Review. 1995.;69(2):274-284.
Gondolf, E.W., and Russell, D. The case against anger control treatment for batterers. Response to the Victimization of Women and Children. 1986.;9:2-5.
Gorney, B. Domestic violence and chemical dependency: Dual problems and dual interventions. Journal of Psychoactive Drugs. 1989.;21:229-238. [pmid: 2668487].
Graham, K. Theories of intoxicated aggression. Canadian Journal of Behavioural Science. 1980.;12:141-158.
Hamberger, L.K., and Hastings, J.E. Personality correlates of men who abuse their partners: A cross-validation study. Journal of Family Violence. 1986a.;1:323-341.
Hamberger, L.K., and Hastings, J.E. "Skills training for treatment of spouse abusers: An outcome study." Paper presented at the annual meeting of the American Psychological Association, Washington, DC, August. 1986b.
Hamilton, C.J., and Collins, J.J. The role of alcohol in wife beating and child abuse: A review of the literature. In: Collins, J.J., ed. Drinking and Crime: Perspectives on the Relationship Between Alcohol Consumption and Criminal Behavior. New York: Guilford, 1981. pp. 253-287.
Hampton, R.L.; Gullotta, T.P.; Adams, G.R.; and Potter, E.H., eds. Issues in Children's and Families' Lives. Vol. 1, Family Violence: Prevention and Treatment. Newbury Park, CA: Sage Publications, 1993.
Harrison, P.A.; Hoffman, N.G.; and Edwall, G.E. Differential drug use patterns among sexually abused adolescent girls in treatment for chemical dependency. International Journal of the Addictions. 1989.;24(6):499-514. [pmid: 2599679].
Hart, B. Beyond the "duty to warn": A therapist's duty to protect. In: Yllo, K., and Bograd, M., eds. Feminist Perspectives on Wife Abuse. Newbury Park, CA: Sage Press, 1988. pp. 234-248.
Hart, B.J. State codes on domestic violence: Analysis, commentary and recommendations. Juvenile and Family Law Digest 25(1), 1992.
Hart, B.J. Children of domestic violence: Risks and remedies. In: New York State Office for Prevention of Domestic Violence. Domestic Violence: The Alcohol and Other Drug Connection. Renssalaer, NY: New York State Office for Prevention of Domestic Violence, 1995a. pp. 21-25.
Hart, B.J. "Coordinated community approaches to domestic violence." Paper presented at the Violence Against Women Research, Strategic Planning Workshop, National Institute of Justice, Washington, DC. 1995b.
Hart, B.J. The Violence Against Women Act: Identifying Projects for Law Enforcement and Prosecution Grants: FY95 Funding. Harrisburg, PA: Battered Women's Justice Project and National Resource Center on Domestic Violence. 1995c.
Hart, B.J.; Edleson, J.L.; Ghez, M.E.; Ford, D.A.; and Gondolf, E.W. Report of the Violence Against Women Research Strategic Planning Workshop. Washington, DC: National Institute of Justice. 1995.
Hawkins, D.J.; Arthur, M.W.; and Catalano, R.F. Preventing substance abuse. In: Tonry, M., and Farrington, D., eds. Crime and Justice: A Review of Research. Vol. 19, Building a Safer Society: Strategic Approaches to Crime Prevention. Chicago: University of Chicago Press, 1995.
Hayes, H.R., and Emshoff, J.G. Substance abuse and family violence. In: Hampton, R.L.; Gullotta, T.P.; Adams, G.R.; and Potter, E.H., ed. Issues in Children's and Families' Lives. Vol. 1, Family Violence: Prevention and Treatment. Newbury Park, CA: Sage Publications, 1993. pp. 281-310.
Hein, Hien, D., and Scheier, J. Trauma and short-term outcome for women in detoxification. Journal of Substance Abuse Treatment. 1996;13:227-231. [pmid: 9017565].
Hesselbrock, M.N.; Meyer, R.E.; and Keener, J.J. Psychopathology in hospitalized alcoholics. Archives of General Psychiatry. 1985.;42:1050-1055. [pmid: 4051682].
Hofford, M.; Bailey, C.; Davis, J.; and Hart, B. Family violence in child custody statutes: An analysis of state codes and legal practice. Family Law Quarterly. 1995.;29(2):197-227.
Holtzworth-Munroe, A., and Stuart, G. Typologies of male batterers: Three subtypes and the differences among them. Psychological Bulletin. 1994.;116(3):476-497. [pmid: 7809309].
Hotaling, G.T., and Sugarman, D.B. An analysis of risk markers in husband to wife violence: The current state of knowledge. Violence and Victims. 1986.;1:101-124. [pmid: 3154143].
Hotaling, G.T., and Sugarman, D.B. A risk marker analysis of assaulted wives. Journal of Family Violence. 1990.;5(1):1-13.
Hyman, A.; Schillinger, D.; and Lo, B. Laws mandating reporting of domestic violence: Do they promote patient well-being?. Journal of the American Medical Association. 1995.;273(22):1781-1787. [pmid: 7769774].
Institute of Medicine, Committee on Prevention of Mental Disorders. Reducing Risks for Mental Disorders: Frontiers for Preventive Intervention Research. Washington, DC: National Academy Press. 1994.
Jaffe, P.; Wilson, S.; and Wolfe, D.A. Promoting changes in attitudes and understanding of conflict resolution among child witnesses of family violence. Canadian Journal of Behavioural Sciences. 1986.;18:356-366.
Kalmuss, D. The intergenerational transmission of marital aggression. Journal of Marriage and Family. 1984.;46:11-19.
Kantor, G.K., and Straus, M.A. The "drunken bum" theory of wife beating. Social Problems. 1987.;34(3):213-227.
Kantor, G., and Straus, M.A. Substance abuse as a precipitant of wife abuse victimizations. American Journal of Drug and Alcohol Abuse. 1989.;15:173-189. [pmid: 2729225].
Kaufman, J., and Zigler, E. The intergenerational transmission of violence is overstated. In: Gelles, R.J., and Loseke, D.R., eds. Current Controversies on Family Violence. Newbury Park, CA: Sage Publications, 1993. pp. 167-196.
Kemp, A.; Rawlings, E.I.; and Green, B.L. Post-traumatic stress disorder (PTSD) in battered women: A shelter sample. Journal of Traumatic Stress. 1991.;4(1):137-148.
Klein, C.F., and Orloff, L.E. Providing legal protection for battered women: An analysis of state statutes and case law. Hofstra Law Review. 1993.;21:801-1188.
Koop, C.E., and Lundberg, G.D. Violence in America: A public health emergency. Journal of the American Medical Association. 1992.;267:3075-3076. [pmid: 1290487].
Koss, M.P., and Harvey, M.R. The Rape Victim: Clinical and Community Approaches to Treatment. Lexington, MA: S. Greene Press. 1987.
Kroll, P.; Stock, D.; and James, M. The behavior of adult alcoholic men abused as children. Journal of Nervous and Mental Disease. 1985.;173:689-693. [pmid: 4056784].
Kurtz, P.D. Maltreatment and the school-aged child: School performance consequences. Child Abuse and Neglect. 1994. 1993.;17:581-589. [pmid: 8221213].
Labell, L.S. Wife abuse: A sociological study of battered women and their mates. Victimology. 1979.;4(2):258-267.
Lang, A.R.; Broeckner, Goeckner, D.J.; Adesso, V.T.; and Marlatt, G.A. The effects of alcohol on aggression in male social drinkers. Journal of Abnormal Psychology. 1975.;84:508-518. [pmid: 1194512].
Langford, D.R. Policy issues for improving institutional response to domestic violence. Journal of Nursing Administration. 1996.;26(1):39-45.
Legal Action Center. Confidentiality: A Guide to the Federal Law and Regulations. New York: Legal Action Center, 1995.
Leonard, K.E., and Jacob, T. Alcohol, alcoholism, and family violence. In: Van Hasselt, V.D.; Morrison, R.L.; Bellack, A.S.; and Herson, M., eds. Handbook of Family Violence. New York: Plenum, 1987. pp. 383-406.
Loring, M.T., and Smith, R.W. Health care barriers and interventions for battered women. Public Health Reports. 1994.;109(3):328-338. [pmid: 8190856].
Lynch, E.W., and Hanson, M.J., eds. Developing Cross-Cultural Competence: A Guide for Working With Young Children and Their Families. Baltimore: Paul H. Brookes. 1992.
MacAndrew, C., and Edgerton, R. Drunken Comportment: A Social Explanation. Chicago: Aldine. 1969.
MacDonald, J.G. Predictors of treatment for alcoholic women. International Journal of the Addictions. 1987.;22:235-248. [pmid: 3583476].
Marlatt, G.A., and Rohsenow, D.J. Cognitive processes in alcohol use: Expectancy and the balanced placebo design. In: Mello, N.K., ed. Advances in Substance Abuse Behavioral and Biological Research. Greenwich, CT: Jai Press, 1980. pp. 159-199.
McClelland, D.C. Power: The Inner Experience. New York: Wiley. 1975.
McCloskey, L.A.; Figueredo, A.J.; and Koss, M.P. The effects of systemic family violence on children's mental health. Child Development. 1995.;66:1239-1261. [pmid: 7555214].
McCurdy, K., and Daro, D. Current Trends in Child Abuse Reporting and Fatalities: The Results of the 1993 Annual Fifty State Survey. Chicago: National Committee to Prevent Child Abuse. 1994.
McFarlane, J.; Christoffel, K.; Bateman, L.; Miller, V.; and Bullock, L. Assessing for abuse: Self-report versus nurse interview. Public Health Nursing. 1991.;8:245-250. [pmid: 1766908].
McFarlane, J., and Parker, B. Abuse During Pregnancy: A Protocol for Prevention and Intervention. White Plains, NY: The March of Dimes Births Defects Foundation. 1994.
McKay, M.M. The link between domestic violence and child abuse: Assessment and treatment considerations. Child Welfare. 1994.;73(1):29-39. [pmid: 8299407].
McLeer, S.V., and Anwar, R.A.H. The role of the emergency physician in the prevention of domestic violence. Annals of Emergency Medicine. 1987.;16:1155-1161. [pmid: 3662163].
McLeer, S., and Anwar, R. A study of battered women presenting in an emergency department. American Journal of Public Health. 1989.;79(1):85-66.
Miller, B. The interrelationships between alcohol and drugs and family violence. In: De La Rosa, M.; Lambert, E.; and Gropper, B., eds. Drugs and Violence: Causes, Correlates, and Consequences. NIDA Research Monograph Series, Number 103. DHHS Pub. No. (ADM) 90-1721. Rockville, MD: National Institute on Drug Abuse, 1990. pp. 177-207.
Miller, B.A.; Downs, W.R.; and Gondoli, D.M. Spousal violence among alcoholic women as compared to a random household sample of women. Journal of Studies on Alcoholism. 1989.;50(6):533-540.
Miller, B.A.; Downs, W.R.; and Testa, M. Interrelationships between victimization experiences and women's alcohol use. Journal of Studies on Alcohol. 1993.;11(Suppl.):109-117.
Miller, W.R., and Rollnick, S., eds. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford. 1991.
Minnesota Coalition for Battered Women. Improving chemical health services for battered women. In: Minnesota Coalition for Battered Women. Safety First: Battered Women Surviving Violence When Alcohol and Drugs Are Involved. St. Paul: Minnesota Coalition for Battered Women, 1992. pp. 29-47.
Moore, M.H. Public health and criminal justice approaches to prevention. In: Tonry, M., and Farrington, D., eds. Crime and Justice: A Review of Research. Vol. 19, Building a Safer Society: Strategic Approaches to Crime Prevention. Chicago: University of Chicago Press, 1995.
National Institute of Justice. The Cycle of Violence. By Widom, C.S. NCJ-136607. Washington, DC: National Institute of Justice. 1992.
Orlandi, M.A. Defining cultural competence: An organizing framework. In: Orlandi, M.A., ed. Cultural Competence for Evaluators: A Guide for Alcohol and Other Drug Abuse Prevention Practitioners Working With Ethnic/Racial Communities. OSAP Cultural Competence Series, Number 1. DHHS Pub. No. 92-1884. Rockville, MD: Office of Substance Abuse Programs, 1992. pp. 293-299.
Pagelow, M.D. Family Violence. New York: Praeger. 1984.
Palmer, S.E.; Brown, R.A.; and Barrera, M.E. Group treatment program for abusive husbands: Long-term evaluation. American Journal of Orthopsychiatry. 1992.;62(2):276-282. [pmid: 1580345].
Peace at Home. Domestic Violence: The Facts. Boston: Peace at Home. 1995.
Pence, E. Batterer programs: Shifting from community collusion to community confrontation. In: Caesar, P.L., and Hamberger, L.K., eds. Treating Men Who Batter. New York: Springer, 1989. pp. 24-50.
Pence, E., and Paymar, M. Education Groups for Men Who Batter: The Duluth Model. New York: Springer. 1993.
Pernanen, K. Alcohol and crimes of violence. In: Kissin, B., and Begleiter, H., eds. The Biology of Alcoholism. Vol. 4, Social Aspects of Alcoholism. New York: Plenum, 1976. pp. 344-351.
Pernanen, K. Alcohol in Human Violence. New York: Guilford. 1991.
Poirier, L. The importance of screening for domestic violence in all women. The Nurse Practitioner. 1997.;22(5):105-122.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. In search of how people change: Applications to addictive behaviors. American Psychologist. 1992.;47:1102-1114. [pmid: 1329589].
Prochaska, J.O.; Norcross, J.C.; and DiClemente, C.C. Changing for Good. New York: Morrow. 1994a.
Prochaska, J.O.; Velicier Velicer, W.F.; Rossi, J.S.; and Goldstein, M.G. Stages of change and decisional balance for 12 problem behaviors. Health Psychology. 1994b.;13:39-46.
Prothrow-Stith, D. Deadly Consequences. New York: HarperCollins. 1991.
Pynoos, R.S. Traumatic stress and developmental psychopathology in children and adolescents. In: Oldham, J.M.; Riba, M.B.; and Tasman, A., eds. American Psychiatric Press Review of Psychiatry. Vol. 12. Washington, DC: American Psychiatric Press, 1993. pp. 205-238.
Pynoos, R.S.; Frederick, C.; Nadir, K.; Arroyo, W.; Steinberg, A.; Eth, S.; Nunez, F.; and Fairbanks, L. Life threat and post-traumatic stress in school-age children. Archives of General Psychiatry. 1987.;44:1057-1063. [pmid: 3689093].
Randall, T. Domestic violence begets other problems of which physicians must be aware to be effective. Journal of the American Medical Association. 1990.;264:940-943. [pmid: 2376879].
Raphael, J. Prisoners of Abuse: Domestic Violence and Welfare Receipt. Chicago: Taylor Institute. 1996.
Rapp, R.C.; Kelliher, C.W.; Fisher, J.H.; and Hall, F.J. Strengths-based case management: A role in addressing denial in substance abuse treatment. Journal of Case Management. 1994.;3(4):139-144. [pmid: 7735084].
Rasche, C.E. "Given" reasons for violence in intimate relationships. In: Wilson, A., ed. Homicide: The Victim/Offender Connection. Cincinnati, OH: Anderson, 1993.
Ravndal, E., and Vaglum, P. Treatment of female addicts: The importance of relationships to parents, partners, and peers for the outcome. International Journal of the Addictions. 1994.;29(1):115-125. [pmid: 8144265].
Redden, G. Family violence and substance abuse: A vicious cycle perpetuated by isolation. The Source. 1997.;7(1):1-2.
Reed, B. Drug misuse and dependency in women: The meaning and implications of being considered a special population or minority group. International Journal of the Addictions. 1985.;20:13-62. [pmid: 3888859].
Reed, B.G. Linkages: Battering, sexual assault, incest, child sexual abuse, teen pregnancy, dropping out of school and the alcohol and drug connection. In: Roth, P., ed. Alcohol and Drugs Are Women's Issues. Vol. 1, A Review of the Issues. Metuchen, NJ: Scarecrow Press. 1991.
Ridgely, M.S., and Willenbring, M.L. Application of case management to drug abuse treatment: Overview of models and research issues. In: Ashery, R.S., ed. Progress and Issues in Case Management. NIDA Research Monograph Series, Number 127. DHHS Pub. No. (ADM) 92-1946. Rockville, MD: National Institute on Drug Abuse, 1992. pp. 12-33.
Roberts, A.R. Substance abuse among men who batter their mates: The dangerous mix. Journal of Substance Abuse Treatment. 1988.;5:83-87. [pmid: 3392757].
Rodriguez, M.A.; Szupinski Quiroga, S.; and Bauer, H.M. Breaking the silence: Battered women's perspectives on medical care. Archives of Family Medicine. 1996.;5:153-158. [pmid: 8620256].
Rogan, A. Domestic violence and alcohol: Barriers to cooperation. Alcohol Health and Research World. 1985-1986.;10:22-27.
Rohsenow, D.J.; Corbett, R.; and Devine, D. Molested as children: A hidden contribution to substance abuse?. Journal of Substance Abuse Treatment. 1988.;5:13-18. [pmid: 3361621].
Roy, M., ed. Battered Women: A Psychological Study of Domestic Violence. New York: Van Nostrand Reinhold. 1977.
Roy, M. The Abusive Partner: An Analysis of Domestic Battering. New York: Van Nostrand Reinhold. 1982.
Roy, M. Children in the Crossfire: Violence in the Home: How Does It Affect Our Children? Deerfield Beach, FL: Health Communications, Inc. 1988.
Russell, D.E.H. Sexual Exploitation: Rape, Child Sexual Abuse and Workplace Harassment. Beverly Hills, CA: Sage Publishing. 1984.
Ryan, V., and Popour, J. Five Year Women's Plan. Developed by the Capitol Area Substance Abuse Commission for the Office of Substance Abuse, Michigan Department of Health. Lansing, MI: Michigan Deprtment of Health. 1983.
Sackett, D.L.; Haynes, B.; and Tugwell, P. Clinical Epidemiology: A Basic Science for Clinical Medicine, 2nd ed. New York: Little, Brown. 1991.
Saunders, D.G. A typology of men who batter: Three types derived from cluster analysis. American Journal of Orthopsychiatry. 1992.;62:264-275. [pmid: 1580344].
Saunders, D.G., and Hanusa, D. Cognitive-behavioral treatment of men who batter: The short-term effects of group therapy. Journal of Family Violence. 1986.;1(4):357-372.
Schetky, D.H., and Green, A.H. Child Sexual Abuse: A Handbook for Healthcare and Legal Professionals. New York: Brunner/Mazel. 1988.
Selber, P.R., and Taliaferro, E. The Physician's Guide to Domestic Violence. Volcano, CA: Volcano Press, 1994.
Seligman, M.E.P. What You Can Change and What You Can't. New York: Knopf. 1993.
Smith, E.M., and Cloninger, C.R. A prospective twelve-year follow-up of alcoholic women: A prognostic scale for long-term outcome. In: Harris, L.S., ed. Problems of Drug Dependence, 1984: Proceedings of the 46th Annual Scientific Meeting, The Committee on Problems of Drug Dependence, Inc. NIDA Research Monograph Series, Number 55. DHHS Pub. No. ADM 85-1393. Rockville, MD: National Institute on Drug Abuse, 1985. pp. 245-251.
Snow, M.G.; Prochaska, J.O.; and Rossi, J.S. Processes of change in Alcoholics Anonymous: Maintenance factors in long-term sobriety. Journal of Studies on Alcohol. 1994.;55:362-371. [pmid: 8022185].
Sonkin, D.J.; Martin, D.; and Walker, L. The Male Batterer. New York: Springer. 1985.
Stark, E., and Flitcraft, A. Violence among intimates: An epidemiological review. In: Van Hasselt, V.D.; Morrison, R.L.; Bellack, A.S.; and Herson, M., eds. Handbook of Family Violence. New York: Plenum, 1988a. pp. 159-199.
Stark E., and Flitcraft, A. Women at risk: A feminist perspective on child abuse. International Journal of Health Services. 1988b.;18(1):97-118.
Stark, E.; Flitcraft, A.; Zuckerman, D.; Grey, A.; Robison, J.; and Frazier, W. Wife abuse in the Medical Setting: An Introduction for Health Personnel. Monograph Series, Number 7. Washington, DC: Office of Domestic Violence. 1981.
State Justice Institute Conference. Courts and Communities: Confronting Violence in the Family. San Francisco, March 25-28. 1993.
Steele, C., and Josephs, R. Alcohol myopia: Its prized and dangerous effects. American Psychologist. 1990.;45:921-933. [pmid: 2221564].
Stosny, S. Treating Attachment Abuse. New York: Springer. 1995.
Straus, M.A., and Gelles, R.J. How violent are American families: Estimates from the National Family Violence Resurvey and other studies. In: Straus, M.A., and Gelles, R.J., eds. Physical Violence in American Families: Risk Factors and Adaptations to Violence in 8,145 Families. New Brunswick, NJ: Transaction Publishers, 1990. pp. 95-112.
Straus, M.A.; Hamby, S.L.; Boney-McCoy, S.; and Sugarman, D.B. The Revised Conflict Tactics Scale (CTS2): Development and preliminary psychometric data. Journal of Family Issues. 1996.;17(3):283-316.
Straus, M.A., and Kantor, G.K. Corporal punishment of adolescents by parents: A risk factor in the epidemiology of depression, suicide, alcohol abuse, child abuse, and wife beating. Adolescence. 1994.;29:543-561. [pmid: 7832020].
Stroul, B.A. Systems of Care for Children and Adolescents With Severe Emotional Disturbances: What Are the Results? Washington, DC: CASSP Technical Assistance Center, Georgetown University Child Development Center. 1993.
Sullivan, J.M., and Evans, K. Integrated treatment for the survivor of childhood trauma who is chemically dependent. Journal of Psychoactive Drugs. 1994.;26(4):369-378. [pmid: 7884599].
Sullivan, W.P. Case management and community-based treatment of women with substance abuse problems. Journal of Case Management. 1994.;3(4):158-161. [pmid: 7735087].
Tolman, R.M. The development of a measure of psychological maltreatment of women by their male partners. Violence and Victims. 1989.;4:159-177. [pmid: 2487132].
Tolman, R.M. "The validation of the Psychological Maltreatment of Women Inventory." Paper presented at the Fourth International Family Violence Research Conference, Durham, NH, July. 1995.
Tolman, R.M., and Bennett, L.W. A review of the quantitative research on men who batter. Journal of Interpersonal Violence. 1990.;5(1):87-118.
Tolman, R.M., and Saunders, D.G. The case for the cautious use of anger control with men who batter. Response to the Victimization of Women and Children. 1988.;11(2):15-20.
Velicier, W.F.; DiClemente, C.C.; Rossi, J.S.; and Prochaska, J.O. Relapse prevention and self-efficacy: An integrative model. Addictive Behaviors. 1990.;15:271-283. [pmid: 2378287].
Walker, L. The Battered Woman. New York: Harper & Row. 1979.
Walker, L.E.A. Psychological impact of the criminalization of domestic violence on victims. Victimology: An International Journal. 1987.;10:281-300.
Walker, L.E.A. Posttraumatic stress disorder in women: Diagnosis and treatment of battered woman syndrome. Psychotherapy. 1991.;28:21-29.
Walker, L.E.A. Abused Women and Survivor Therapy: A Practical Guide for the Psychotherapist. Washington, DC: American Psychological Association. 1994.
Willenbring, M.L. Case management applications in substance use disorders. Journal of Case Management. 1994.;3(4):150-157. [pmid: 7735086].
Wilsnack, S.C. Drinking, sexuality, and sexual dysfunction in women. In: Wilsnack, S.C., and Beckman, L.J., eds. Alcohol Problems in Women: Antecedents, Consequences, and Intervention. New York: Guilford, 1980. pp. 263-298.
Wilson, M. Marital conflict and homicide in an evolutionary perspective. In: Bell, R.W., and Bell, N.J., eds. Sociobiology and the Social Sciences. Lubbock, TX: Texas Tech University Press, 1989. pp. 45-62.
Windle, M.; Windle, R.C.; Scheidt, D.M.; and Miller, G.B. Physical and sexual abuse and associated mental disorders among alcoholic inpatients. American Journal of Psychiatry. 1995.;152:1322-1328. [pmid: 7653688].
Wolk, J.L.; Hartmann, D.J.; and Sullivan, W.P. Defining success: The politics of evaluation in alcohol and drug abuse treatment programs. Journal of Sociology and Social Welfare. 1994.;21(4):133-145.
Woods, S.J., and Campbell, J.C. Posttraumatic stress in battered women: Does the diagnosis fit?. Issues in Mental Health Nursing. 1993.;14:173-186. [pmid: 8509278].
Wright, J., and Popham, J. Alcohol and battering: The double bind. In: New York State Office for Prevention of Domestic Violence. Domestic Violence: The Alcohol and Other Drug Connection. Rensselaer, NY: New York State Office for Prevention of Domestic Violence, 1995. pp. 128-134.
Zawitz, M.W.; Klaus, P.A.; Bachman, R.; Bastian, L.D.; DeBerry, M.M., Jr.; Rand, M.R.; and Taylor, B.M. Highlights From 20 Years of Surveying Crime Victims: The National Crime Victimization Survey, 1973-1992. NCJ Pub. No. 144525. Washington, DC: Bureau of Justice Statistics. 1993.
Zorza, J. Mandatory arrest for domestic violence: Why it may prove the best first step in curbing repeat abuse. Criminal Justice. 1995a.;10(3):2-4, 6, 8, 9, 51-54.
Zorza J. Recognizing and protecting the privacy and confidentiality needs of battered women. Family Law Quarterly. 1995b.;29(2):273-311.
Zubretsky, T.M., and Digirolamo, K.M. The false connection between adult domestic violence and alcohol. In: Roberts, A.R., ed. Helping Battered Women. New York: Oxford University Press, 1996. pp. 223-228.