# Consensus Panel

Co-Chairs
- Eleanor Sullivan, Ph.D., R.N., F.A.A.N.
- Professor and Former Dean
- School of Nursing
- University of Kansas
- Kansas City, Kansas
- Michael Fleming, M.D., M.P.H.
- Associate Professor
- Department of Family Medicine
- University of Wisconsin
- Madison, Wisconsin

Workgroup Leaders
- Michael J. Bohn, M.D.
- Assistant Professor
- Department of Psychiatry
- University of Wisconsin Medical School
- Madison, Wisconsin
- Myra Muramoto, M.D.
- Assistant Professor
- Department of Family and Community Medicine
- University of Arizona
- Tucson, Arizona
- Madeline A. Naegle, R.N., Ph.D., F.A.A.N.
- Associate Professor
- Division of Nursing
- New York University
- New York, New York
- Daniel Vinson, M.D., M.S.P.H.
- Assistant Professor
- Department of Family and Community Medicine
- Columbia School of Medicine
- University of Missouri
- Columbia, Missouri
- Allen Zweben, D.S.W.
- Director and Associate Professor of Social Work
- Center for Addiction and Behavioral Health Research
- School of Social Welfare
- University of Wisconsin at Milwaukee
- Milwaukee, Wisconsin

Panelists
- Steven Adelman, M.D.
- Addiction Medicine Consultant
- Harvard Community Health Plan
- Harvard Pilgrim Health Care
- West Roxbury, Massachusetts
- Machelle H. Allen, M.D.
- Assistant Professor
- Department of Obstetrics and Gynecology
- School of Medicine
- New York University
- New York, New York
- Kathleen Austin, C.D.C. III, N.C.A.C. II
- Alcohol Therapist II
- Adult Medicine/Ambulatory Care
- Harborview Medical Center
- Seattle, Washington
- Mark L. Carlson, M.D.
- Medical Director
- Cox Care Substance Abuse Treatment Center
- Cox Health Systems, Inc.
- Springfield, Missouri
- Theodore M. Godlaski, M.Div., I.C.D.C.
- Director of Community Treatment Project
- Center for Alcohol and Drug Research
- University of Kentucky
- Lexington, Kentucky
- Derrick Harris, L.C.S.W., C.A.C. II
- Director of Outpatient Services
- Clitheroe Center
- Salvation Army
- Anchorage, Alaska
- Susan Hernandez
- Assessment Supervisor
- Southwest Migrant Farm Workers and Native American (TIGUA) Assistance Program
- West Texas Council on Alcoholism and Drug Abuse
- El Paso, Texas
- Mark L. Kraus, M.D.
- Medical Director
- Addiction Medicine
- Waterbury Hospital
- Waterbury, Connecticut
- E. Joyce Roland, Ph.D.
- Research Psychologist
- Center for Social Research and Policy Analysis
- Research Triangle Institute
- Research Triangle Park, North Carolina
- Marilyn Sawyer Sommers, Ph.D., R.N.
- Associate Professor
- College of Nursing
- University of Cincinnati
- Cincinnati, Ohio
- Robert Taylor, M.D., Ph.D.
- Chairman
- Department of Pharmacology
- College of Medicine
- Howard University
- Washington, D.C.