# Editorial Advisory Board

- Karen Allen, Ph.D., R.N., C.A.R.N.
- President of the National Nurses Society on Addictions
- Associate Professor
- Department of Psychiatry, Community Health, and Adult Primary Care
- University of Maryland
- School of Nursing
- Baltimore, Maryland

- Richard L. Brown, M.D., M.P.H.
- Assistant Professor
- Department of Family Medicine
- University of Wisconsin School of Medicine
- Madison, Wisconsin

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Linda S. Foley, M.A.
- Former Director
- Project for Addiction Counselor Training
- National Association of State Alcohol and Drug Directors
- Washington, D.C.

- Wayde A. Glover, M.I.S., N.C.A.C. II
- Director
- Commonwealth Addictions Consultants and Trainers
- Richmond, Virginia

- Pedro J. Greer, M.D.
- Assistant Dean for Homeless Education
- University of Miami School of Medicine
- Miami, Florida

- Thomas W. Hester, M.D.
- Former State Director
- Substance Abuse Services
- Division of Mental Health, Mental Retardation and Substance Abuse
- Georgia Department of Human Resources
- Atlanta, Georgia

- Gil Hill
- Director
- Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Douglas B. Kamerow, M.D., M.P.H.
- Director
- Office of the Forum for Quality and Effectiveness in Health Care
- Agency for Health Care Policy and Research
- Rockville, Maryland

- Stephen W. Long
- Director
- Office of Policy Analysis
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center
- Los Angeles, California

- Ellen A. Renz, Ph.D.
- Former Vice President of Clinical Systems
- MEDCO Behavioral Care Corporation
- Kamuela, Hawaii

- Richard K. Ries, M.D.
- Director and Associate Professor
- Outpatient Mental Health Services and Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

- Sidney H. Schnoll, M.D., Ph.D.
- Chairman
- Division of Substance Abuse Medicine
- Medical College of Virginia
- Richmond, Virginia