# Appendix E -- Bibliography

Abel, E.A., and Sokol, R.J. A revised conservative estimate of the incidence of FAS and its economic impact. Alcohol: Clinical and Experimental Research. 1991;15:514-524.
Adams, W.L.; Yuan, Z.; Barboriak, J.J.; and Rimm, A.A. Alcohol-related hospitalizations of elderly people. Prevalence and geographic location in the United States. Journal of the American Medical Association. 1993;270(10):1222-1225. [pmid: 8355385].
Agency for Health Care Policy and Research. Smoking Cessation: A Guide for Primary Care Clinicians. Pub. No. 96-0693. Rockville, MD: Agency for Health Care Policy and Research, 1996. http://www.ahcpr.gov/clinic/smokepcc.htm [Accessed June 19, 1997].
Allen, J.P.; Maisto, S.A.; and Connors, G.J. Self-report screening tests for alcohol problems in primary care. Archives of Internal Medicine. 1995;155(16):1726-1730. [pmid: 7654105].
American Medical Association, Council on Scientific Affairs. AMA Guidelines for Physician Involvement in the Care of Substance-Abusing Patients. Chicago: The American Medical Association. 1979a.
American Medical Association, Council on Scientific Affairs. Guidelines for Alcoholism Diagnosis, Treatment and Referral. Chicago: American Medical Association. 1979b.
American Medical Association, Council on Scientific Affairs. Alcohol and the driver. Journal of the American Medical Association. 1986;255:522-527.
American Medical Association. Alcoholism in the Elderly: Diagnosis, Treatment, Prevention. Guidelines for Primary Care Physicians. Chicago: American Medical Association. 1995.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC: American Psychiatric Association. 1994a.
American Psychiatric Association. The Quick Reference to the Diagnostic Criteria from DSM-IV. Washington, DC: American Psychiatric Association. 1994b.
American Psychiatric Association. Practice Guidelines for Treatment of Patients With Substance Use Disorders: Alcohol, Cocaine, Opioids. Washington, DC: American Psychiatric Association. 1995.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Substance-Related Disorders. 2nd ed. Washington, DC: American Society of Addiction Medicine. 1996.
Anthenelli, R.M., and Schuckit, M.A. Genetics. In: Lowinson, J.H.; Ruiz, P.; and Millman, R.B., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins, 1992. pp. 39-50.
Antti-Poika, I.; Karaharju, E.; Roine, R.; and Salaspuro, M. Intervention of heavy drinking: A prospective and controlled study of 438 consecutive injured male patients. Alcohol and Alcoholism. 1988;23(2):115-121. [pmid: 3390235].
Azrin, N.H.; McMahon, P.T.; Donohue, B.; Besalel, V.; Lapinski, K.J.; Kogan, E.S.; Acierno, R.E.; and Falloway, E. Behavior therapy for drug abuse: A controlled treatment outcome study. Behaviour Research and Therapy. 1994;32(8):857-866. [pmid: 7993330].
Babor, T.F.; Brown, J.; and DelBoca, F.K. Validity of self-reports in applied research on addictive behaviors: Fact or fiction?. Behavioral Assessment. 1990;12:5-31.
Babor, T.F.; de la Fuente, J.R.; Saunders, J.; and Grant, M. AUDIT: The Alcohol Use Disorders Identification Test: Guidelines for Use in Primary Health Care. Geneva, Switzerland: World Health Organization. 1992.
Babor, T.F., and Grant, M., eds. Project on Identification and Management of Alcohol-Related Problems. Report on Phase II: A Randomized Clinical Trial of Brief Interventions in Primary Health Care. Geneva, Switzerland: World Health Organization. 1992.
Babor, T.F.; Kranzler, H.R.; and Lauerman, R.J. Early detection of harmful alcohol consumption: Comparison of clinical, laboratory, and self-report screening procedures. Addictive Behaviors. 1989;14(2):139-157. [pmid: 2728952].
Balas, E.A.; Austin, S.M.; Mitchell, J.A.; Ewigman, B.G.; Bopp, K.D.; and Brown, G.D. The clinical value of computerized information services: A review of 98 randomized clinical trials. Archives of Family Medicine. 1996;5:271-278.
Bandstra, E.S., and Burkett, G. Maternal-fetal and neonatal effects of in utero cocaine exposure. Seminars in Perinatology. 1991;15(4):288-301. [pmid: 1948140].
Barry, K.L., and Fleming, M.F. Computerized administration of alcoholism screening tests in a primary care setting. Journal of the American Board of Family Practice. 1990;3:93-98.
Barry, K.L., and Fleming, M.F. The Alcohol Use Disorders Identification Test (AUDIT) and the SMAST-13: Predictive validity in a rural primary care sample. Alcohol and Alcoholism. 1993;28(1):33-42. [pmid: 8471085].
Beck, A.T. Beck Depression Inventory. Philadelphia, PA: Center for Cognitive Therapy. 1961.
Beresford, T.P.; Blow, F.C.; Hill, E.; Singer, K.; and Lucey, M.R. Comparison of CAGE questionnaire and computer-assisted laboratory profiles for screening for covert alcoholism. Lancet. 1990;336(8713):482-485. [pmid: 1974998].
Bernadt, M.W.; Mumford, J.; Taylor, C.; Smith, B.; and Murray, R.M. Comparison of questionnaire and laboratory tests in the detection of excessive drinking and alcoholism. Lancet. 1982;1(8267):325-328. [pmid: 6120322].
Berwick, D.M. From measuring to managing the improvement of prevention. American Journal of Preventive Medicine. 1995;11:385-387.
Bien, T.H.; Miller, W.R.; and Tonigan, J.S. Brief interventions for alcohol problems: A review. Addiction. 1993;88:315-336.
Blouin, A.G.; Perez, E.L.; and Blouin, J.H. Computerized administration of the Diagnostic Interview Schedule. Psychiatry Research. 1988;23:335-344.
Blow, F.C.; Brower, K.J.; Schulenberg, J.E.; Demo-Dananberg, L.M.; Young, J.P.; and Beresford, T.P. The Michigan Alcoholism Screening Test—Geriatric Version (MAST-G): A new elderly specific screening instrument. Alcoholism: Clinical and Experimental Research. 1992;16:372.
Bohn, M.J.; Babor, T.F.; and Kranzler, H.R. The Alcohol Use Disorders Identification Test (AUDIT): Validation of a screening instrument for use in medical settings. Journal of Studies on Alcohol. 1995;56(4):423-432. [pmid: 7674678].
Brook, D.W., and Brook, J.S. The etiology and consequences of adolescent drug use. In: Watson, R.R., ed. Drug and Alcohol Abuse Prevention. Clifton, NJ: Humana Press, 1990.
Brown, R.L. Identification and office management of alcohol and drug disorders. In: Fleming, M.F., and Barry, K.L., eds. Addictive Disorders. Baltimore, MD: Mosby Yearbook, 1992. pp. 25-43.
Brown, R.L., and Rounds, L.A. Conjoint screening questionnaires for alcohol and other drug abuse: Criterion validity in a primary care practice. Wisconsin Medical Journal. 1995;94(3):135-140. [pmid: 7778330].
Buchsbaum, D.G.; Buchanan, R.G.; Centor, R.M.; Schnoll, S.H.; and Lawton, M.J. Screening for alcohol abuse using CAGE scores and likelihood ratios. Annals of Internal Medicine. 1991;115:774-777.
Buchsbaum, D.G.; Welsh, J.; Buchanan, R.G.; and Elswich, R.K., Jr. Screening for drinking problems by patient self-report. Even "safe" levels may indicate a problem. Archives of Internal Medicine. 1995;155(1):104-108. [pmid: 7802509].
Center for Substance Abuse Treatment. Pregnant, Substance-Using Women. Treatment Improvement Protocol (TIP) Series, Number 2. DHHS Pub. No. (SMA) 93-1998. Washington, DC: U.S. Government Printing Office. 1993a.
Center for Substance Abuse Treatment. Screening and Assessment of Alcohol- and Other Drug-Abusing Adolescents. Treatment Improvement Protocol (TIP) Series, Number 3. DHHS Pub. No. (SMA) 93-2009. Washington, DC: U.S. Government Printing Office. 1993b.
Center for Substance Abuse Treatment. Guidelines for the Treatment of Alcohol- and Other Drug-Abusing Adolescents. Treatment Improvement Protocol (TIP) Series, Number 4. DHHS Pub. No. (SMA) 93-2010. Washington, DC: U.S. Government Printing Office. 1993c.
Center for Substance Abuse Treatment. Intensive Outpatient Treatment for Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 8. DHHS Pub. No. (SMA) 94-2077. Washington, DC: U.S. Government Printing Office. 1994a.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients with Coexisting Mental Illness and Alcohol and Other Drug Abuse. Treatment Improvement Protocol (TIP) Series, Number 9. DHHS Pub. No. (SMA) 94-2078. Washington, DC: U.S. Government Printing Office. 1994b.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Treatment Improvement Protocol (TIP) Series, Number 11. DHHS Pub. No. (SMA) 94-2094. Washington, DC: U.S. Government Printing Office. 1994c.
Center for Substance Abuse Treatment. The Role and Current Status of Patient Placement Criteria in the Treatment of Substance Use Disorders. Treatment Improvement Protocol (TIP) Series, Number 13. DHHS Pub. No. (SMA) 95-3021. Washington, DC: U.S. Government Printing Office. 1995a.
Center for Substance Abuse Treatment. Alcohol and Other Drug Screening of Hospitalized Trauma Patients. Treatment Improvement Protocol (TIP) Series, Number 16. DHHS Pub. No. (SMA) 95-3041. Washington, DC: U.S. Government Printing Office. 1995b.
Center for Substance Abuse Treatment. Detoxification from Alcohol and Other Drugs. Treatment Improvement Protocol (TIP) Series, Number 19. DHHS Pub. No. (SMA) 95-3046. Washington, DC: U.S. Government Printing Office. 1995c.
Center for Substance Abuse Treatment. The National Treatment Improvement Evaluation Study. Preliminary Report: The Persistent Effects of Substance Abuse Treatment—One Year Later. Rockville, MD: Center for Substance Abuse Treatment, September. 1996.
Center on Addiction and Substance Abuse. The Cost of Substance Abuse to America's Health Care System. New York: Center on Addiction and Substance Abuse. 1993.
Centers for Disease Control and Prevention. Fetal Alcohol Syndrome—United States, 1979-1992. Morbidity and Mortality Weekly Report. 1993;42:339-341.
Chafetz, M.E. A procedure for establishing contact with the alcoholic. Quarterly Journal of Studies on Alcohol. 1961;22:325-328.
Chafetz, M.E. Research in the alcohol clinic: An around the clock psychiatric service of the Massachusetts General Hospital. American Journal of Psychiatry. 1968;124:1634-1679.
Chafetz, M.E.; Blane, H.T.; Abram, H.S.; and Golner, J. Establishing treatment relations with alcoholics. Journal of Nervous and Mental Disease. 1962;134:395-409.
Chafetz, M.E.; Blane, H.T.; and Clark, E. Establishing treatment relations with alcoholics: A supplementary report. Journal of Nervous and Mental Disease. 1964;138:390-393.
Chan, A.W.; Pristach, E.A.; Welte, J.W.; and Russell, M. Use of the TWEAK test in screening for alcoholism/heavy drinking in three populations. Alcoholism: Clinical and Experimental Research. 1993;17(6):1188-1192.
Chastain, S. The accidental addict. Modern Maturity. 1992;35(1).
Cherpitel, C.J. Breath analysis and self-reports as measures of alcohol-related emergency room admissions. Journal of Studies on Alcohol. 1989;50(2):155-161. [pmid: 2927129].
Cherpitel, C.J. Screening for alcohol problems in the emergency room: A rapid alcohol problems screen. Drug and Alcohol Dependence. 1995;40(2):133-137. [pmid: 8745135].
Cherpitel, C.J., and Clark, W.B. Ethnic differences in performance of screening instruments for identifying harmful drinking and alcohol dependence in the emergency room. Alcoholism: Clinical and Experimental Research. 1995;19(3):628-634.
Chick, J.; Lloyd, G.; and Crombie, E. Counseling problem drinkers in medical wards: A controlled study. British Medical Journal. 1984;290:965-967.
Chick, J.; Ritson, B.; Connaughton, J.; Stewart, A.; and Chick, J. Advice versus extended treatment for alcoholism: A controlled study. British Journal of Addictions. 1988;83:159-170.
Cleary, P.D.; Miller, M.; Bush, B.T.; Warburg, M.M.; Delbanco, T.L.; and Aronson, M.D. Prevalence and recognition of alcohol abuse in a primary care population. American Journal of Medicine. 1988;85:466-471.
Cohen, S.J.; Christen, A.G.; Katz, B.P.; Drook, C.A.; Davis, B.J.; Smith, D.M.; and Stookey, G.K. Counseling medical and dental patients about cigarette smoking: The impact of nicotine gum and chart reminders. American Journal of Public Health. 1987;77:313-316.
College of Family Physicians of Canada. Alcohol Risk Assessment and Intervention (ARAI): Resource Manual for Family Physicians. Ontario, Canada: The College of Family Physicians of Canada. 1994.
Collins, A.C. Genetics as a tool for identifying biological markers of drug abuse. In: Braude, M.C., and Chao, H.M., eds. Genetic and Biological Markers in Drug Abuse and Alcoholism. NIDA Research Monograph Series, Number 66. ADM Pub. No. 86-1444. Rockville, MD: National Institute on Drug Abuse, 1986. pp. 57-70.
Community Epidemiology Work Group. Epidemiologic Trends in Drug Abuse—December 1995. Volume I: Highlights and Executive Summary. Pub. No. (ADM) 96-4128. Rockville, MD: National Institute on Drug Abuse. 1996.
Cummings, S.R.; Coates, T.J.; Richard, R.J.; Hansen, B.; Zahnd, E.G.; VanderMartin, R.; Duncan, C.; Gerbert, B.; Martin, A.; and Stein, M.J. Training physicians in counseling about smoking cessation: A randomized trial of the "Quit for Life" program. Annals of Internal Medicine. 1989;110:640-647.
Davis, D.A.; Thomson, M.A.; Oxman, A.D.; and Haynes, R.B. Changing physician performance: A systematic review of the effect for continuing medical education strategies. Journal of the American Medical Association. 1995;274:700-705.
Dawson, D.A., and Grant, B.F. Family history and gender: Their combined effects on DSM-IV alcohol dependence and major depression. Journal of Studies on Alcohol. in press.
DeHart, S.S., and Hoffmann, N.G. Screening and diagnosis of "alcohol abuse and dependence" in older adults. The International Journal of the Addictions. 1995;30(13&14):1717-1747.
Drummond, D.C.; Thom, B.; Brown, C.; Edwards, G.; and Mullan, J. Specialist versus general practitioner treatment of problem drinkers. Lancet. 1990;336:915-918.
Dube, C.E., and Lewis, D.C., eds. Project ADEPT Curriculum for Primary Care Physician Training. Providence, RI: Brown University. 1994.
Edwards, G., and Orford, J. A plain treatment for alcoholism. Proceedings of the Royal Society of Medicine. 1977;70:344-348.
Edwards, G.; Orford, J.; Egert, S.; Guthrie, S.; Hawker, A.; Hensman, C.; Mitcheson, M.; Oppenheimer, E.; and Taylor, C. Alcoholism: A controlled trial of treatment and advice. Journal of Studies on Alcohol. 1977;38(5):1004-1031. [pmid: 881837].
Elster, A.B., and Kuznets, N.J. AMA Guidelines for Adolescent Preventive Services (GAPS): Recommendations and Rationale. Baltimore, MD: Williams & Wilkins. 1994.
Elvy, G.A.; Wells, J.E.; and Baird, K.A. Attempted referral as intervention for problem drinking in the general hospital. British Journal of Addiction. 1988;83:83-89.
Ewing, J.A. Detecting alcoholism: The CAGE Questionnaire. Journal of the American Medical Association. 1984;252:1905-1907.
Finigan, M. Societal Outcomes of Drug and Alcohol Treatment in the State of Oregon. 1996.
Finney, J.W., and Monahan, S.C. The cost effectiveness of treatment for alcoholism: A second approximation. Journal of Studies on Alcohol. 1996;57:229-243.
Fleming, M.F. Competencies for substance abuse training. In: Sirica, C., ed. Training About Alcohol and Substance Abuse for all Primary Care Physicians. A Conference Sponsored by the Josiah Macy, Jr., Foundation. New York: Josiah Macy, Jr., Foundation, 1995. pp. 213-247.
Fleming, M.F., and Barry, K.L. A three-sample test of a masked alcohol screening questionnaire. Alcohol & Alcoholism. 1991;26(1):81-91. [pmid: 1854376].
Fleming, M.F., and Barry, K.L. Clinical overview of alcohol and drug disorders. In: Fleming, M.F., and Barry, K.L., eds. Addictive Disorders. Chicago: Mosby Yearbook, 1992. pp. 3-21.
Fleming, M.F.; Barry, K.L.; Davis, A.; Kahn, R.; and Rivo, M. Faculty development in addiction medicine: Project SAEFP, a one-year follow-up study. Family Medicine. 1994;26(4):221-225. [pmid: 8034139].
Fleming, M.F.; Barry, K.L.; and MacDonald, R. The Alcohol Use Disorders Identification Test (AUDIT) in a college sample. The International Journal of the Addictions. 1991;26(11):1173-1185. [pmid: 1743817].
Fleming, M.F.; Barry, K.L.; Manwell, L.B.; Johnson, K.; and London, R. A Trial of Early Alcohol Treatment (Project TrEAT): A randomized trial of brief physician advice in community-based primary care practices. in press.
Fleming, M.; Bruno, M.; Barry, K.; and Fost, N. Informed consent, deception, and the use of disguised alcohol questionnaires. American Journal of Drug and Alcohol Abuse. 1989;15:309-315.
Gardner, E.L. Brain reward mechanisms. In: Lowinson, J.H.; Ruiz, P.; and Millman, R.B., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins, 1992. pp. 70-99.
Gavin, E.R.; Ross, H.E.; and Skinner, H.A. Diagnostic validity of the Drug Abuse Screening Test in the assessment of the DSM-III drug disorders. British Journal of Addiction. 1989;84:301-307.
Gentilello, L.M.; Cobean, R.A.; Walker, A.P.; Moore, E.E.; Wertz, M.J.; and Dellinger, E.P. Acute ethanol intoxication increases the risk of infection following penetrating abdominal trauma. Journal of Trauma. 1993;34(5):669-674; discussion 674-675.
Gerstein, D.R., and Harwood, H.J., eds. Institute of Medicine. Treating Drug Problems. 1990.
Gibb, K.A.; Yee, A.S.; Johnston, C.C.; Martin, S.D.; and Nowak, R.M. Accuracy and usefulness of a breath alcohol analyzer. Annals of Emergency Medicine. 1984;13(7):516-520. [pmid: 6742553].
Gjerde, H.; Amundsen, A.; Skog, O.J.; Morland, J.; and Aasland, O.G. Serum gamma-glutamyl transferase: An epidemiological indicator of alcohol consumption?. British Journal of Addiction. 1987;82(9):1027-1031. [pmid: 2890368].
Gordis, E., and Allen, J.P. Research opportunities in typology and genetics of alcoholism. Annals of the New York Academy of Science. 1994.
Gorsuch, R.L. Religious aspects of substance abuse and recovery. Journal of Social Issues. 1995;51(2):65-84.
Gorsuch, R.L., and McPherson, S.E. Intrinsic/extrinsic measurement: I/E revised and single item scales. Journal for the Scientific Study of Religion. 1989;28:348-354.
Graham, A. Screening for lifestyle risk assessment in a community hospital. Archives of Internal Medicine. 1991;151:958-964.
Grant, B.F.; Harford, T.C.; Dawson, D.A.; Chou, P.; Dufour, M.; and Pickering, R. Prevalence of DSM-IV alcohol abuse and dependence: United States, 1992. Alcohol Health & Research World. 1994;18(3):243-248.
Hanley-Hazelden Center. How To Talk to an Older Person Who Has a Problem With Alcohol or Medications. 1991.
Hawkins, J.D.; Catalano, R.F.; and Miller, J.Y. Risk and protective factors for alcohol and other drug problems in adolescence and early adulthood: Implications for substance abuse problems. Psychological Bulletin. 1992;112:64-105.
Hawkins, J.D.; Lishner, D.M.; and Catalano, R.F. Childhood predictors and the prevention of adolescent substance abuse. In: Jones, C.L., and Battjes, R.J., eds. Etiology of Drug Abuse: Implications for Prevention. NIDA Research Monograph Series, Number 56. ADM Pub. No. 85-1335. Rockville, MD: National Institute on Drug Abuse, 1985. pp. 75-125.
Hays, R.D.; Hill, L.; and Gillogly, J.J. Response times for the CAGE, Short-MAST, AUDIT, and JELLINEK alcohol scales. Behavioral Research Methods, Instruments, and Computers. 1993;25(2):304-307.
Heath, A.C.; Jardin, R.; and Martin, N.B. Interactive effects of genotype and social environment on alcohol consumption in female twins. Journal of Studies on Alcohol. 1989;59:38-48.
Heather, N.; Kissoon-Singh, J.; and Fenton, G.W. Assisted natural recovery from alcohol problems: Effects of a self-help manual with and without supplementary telephone contact. . British Journal of Addiction. 1990;85:1177-1185.
Heather, N.; Rollnick, S.; and Bell, A. Predictive validity of the readiness to change questionnaire. Addiction. 1993;88:1667-1677.
Heather, N.; Whitton, B.; and Robertson, I. Evaluation of a self-help manual for media-recruited problem drinkers: Six-month follow-up results. British Journal of Clinical Psychology. 1986;5:19-34.
Hjortdahl, P., and Laerum, E. Continuity of care in general practice: Effect on patient satisfaction. British Journal of Medicine. 1992;304:1287-1290.
Holder, H.; Longabaugh, R.; Miller, W.R.; and Rubonis, A.V. The cost effectiveness of treatment for alcoholism: A first approximation. Journal of Studies on Alcohol. 1991;52:517-540.
Hurt, R.D.; Morse, R.M.; and Swenson, W.M. Diagnosis of alcoholism with a self-administered alcoholism screening test: Results with 1002 consecutive patients receiving general examinations. Mayo Clinic Proceedings. 1980;55:365-370.
Institute for Health Policy, Brandeis University. Substance Abuse: The Nation's Number One Health Problem: Key Indicators for Policy. Princeton, NJ: The Robert Wood Johnson Foundation. 1993.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, DC: National Academy Press. 1990.
Institute of Medicine, Committee on the Future of Primary Care. Donaldson, M.S.; Yordy, K.D.; Lohr, K.N.; and Vanselow, N.A., eds. Primary Care: America's Health in a New Era Washington, DC: Institute of Medicine 1996http://www.nap.edu/readingroom/books/primary/summary.html
Johnson, B.D., and Muffler, J. Sociocultural aspects of drug use and abuse in the 1990s. In: Lowinson, J.H.; Ruiz, P.; and Millman, R.B., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins, 1992. pp. 118-137.
Johnston, L.D.; O'Malley, P.M.; and Bachman, J.G. National Survey Results on Drug Use From the Monitoring the Future Study, 1975-1995. Volume I: Secondary School Students. NIH Pub. No. 97-4139. Rockville, MD: National Institute on Drug Abuse. 1996.
Kahan, M.; Wilson, L.; and Becker, L. Effectiveness of physician-based interventions with problem drinkers: A review. Canadian Medical Association Journal. 1995;152(6):851-859. [pmid: 7697578].
Kandel, D.B.; Simcha-Fagan, O.; and Davies, M. Risk factors for delinquency and illicit drug use from adolescence to young adulthood. Journal of Drug Issues. 1986;60:67-90.
Kemper, K.J.; Greteman, A.; Bennett, E.; and Babonis, T.R. Screening mothers of young children for substance abuse. Developmental and Behavioral Pediatrics. 1993;14(5):308-312.
Kessler, R.C.; McGonagle, K.A.; Zhao, S.; Nelson, C.B.; Hughes, M.; Eshleman, S.; Wittchen, H.U.; and Kendler, K.S. Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Archives of General Psychiatry. 1994;51:8-19.
Kibbe, D.C.; Bentz, E.; and McLaughlin, C.P. Continuous quality improvement for continuity of care. Journal of Family Practice. 1993;36:304-308.
Koob, G.E., and Bloom, F.E. Cellular and molecular mechanisms of drug dependence. Science. 1988;242:715-723.
Kristenson, H.; Ohlin, H.; Hulten-Mosslin, M.B.; Trell, E.; and Hood, B. Identification and intervention of heavy drinking in middle-aged men: Results and followup of 24-60 months of long-term study with randomized controls. Alcoholism: Clinical and Experimental Research. 1983;7(2):203-209.
Landry, M.J. Understanding Drugs of Abuse: The Process of Addiction, Treatment, and Recovery. Washington, DC: American Psychiatric Press. 1994.
Landry, M.J. Overview of Addiction Treatment Effectiveness. Pub. No. (SMA) 96-3081. Rockville, MD: Substance Abuse and Mental Health Services Administration. 1996.
Landry, M.J.; Smith, D.E.; McDuff, D.R.; and Baughman, O.L. III. Anxiety and substance use disorders: The treatment of high-risk patients. Journal of the American Board of Family Practice. 1991a;4:447-456.
Landry, M.J.; Smith, D.E.; McDuff, D.R.; and Baughman, O.L. III. Benzodiazepine dependence and withdrawal: Identification and medical management. Journal of the American Board of Family Practitioners. 1991b;5(2):167-175.
Liepman, M.R.; Nirenberg, T.D.; and Begin, A.M. Evaluation of a program designed to help family and significant others to motivate resistant alcoholics into recovery. American Journal of Drug and Alcohol Abuse. 1989;15(2):209-221. [pmid: 2729227].
Longabaugh, R.; Minugh, P.A.; Nirenberg, T.D.; Clifford, P.R.; Becker, B.; and Wollard, R. Injury as a motivator to reduce drinking. Academic Emergency Medicine. 1995;2(9):817-825. [pmid: 7584769].
Maisto, S.A.; McKay, J.R.; and Connors, J.J. Self-report issues in substance abuse: State of the art and future directions. Behavioral Assessment. 1990;12(1):117-134.
Mann, J.J. Psychobiologic predictors of suicide. Journal of Clinical Psychiatry. 1987;48(Suppl. 12):39-43.
Manwell, L.; Fleming, M.F.; Barry, K.; and Johnson, K. Tobacco, alcohol, and drug use in a primary care sample: 90 day prevalence and associated factors. Journal of Addictive Diseases. in press.
Marlatt, G.A.; Baer, J.S.; Donavan, D.M.; and Kivlan, D.R. Addictive behaviors: Etiology and treatment. Annual Review of Psychology. 1988;39:223-252.
McGinnis, J.M., and Foege, W.H. Actual causes of death in the United States. Journal of the American Medical Association. 1993;270:2207-2212.
McGue, M. Genes, environment, and the etiology of alcoholism. In: Zucker, R.; Boyd, G.; and Howard, J., eds. The Development of Alcohol Problems: Exploring the Biopsychosocial Matrix of Risk. NIAAA Research Monograph Series, Number 26. NIH Pub. No. 94-3495. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism, 1994. pp. 1-40.
Meyer, R.E. How to understand the relationship between psychopathology and addictive disorders: Another example of the chicken and the egg. In: Meyer, R.E., ed. Psychopathology and Addictive Disorders. New York, NY: Guilford Press, 1986. pp. 3-16.
Midanik, L.T. Perspectives on the validity of self-reported alcohol use. British Journal on Addiction. 1989;84(12):1419-1423.
Miller, W.R.; Brown, J.M.; Simpson, T.L.; Handmaker, N.S.; Bien, T.H.; Luckie, L.F.; Montgomery, H.A.; Hester, R.K.; and Tonigan, J.S. What works? A methodological analysis.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People To Change Addictive Behavior. New York: Guilford Press. 1991.
Miller, W.R., and Sanchez, V.C. Motivating young adults for treatment and lifestyle change. In: Howard, G.S., and Nathan, P.E., eds. Alcohol Use and Misuse by Young Adults. Notre Dame, IN: University of Notre Dame Press, 1994. pp. 55-81.
Miller, W.R., and Sovereign, R. The check-up: A model for early intervention in addictive behaviors. In: Loberg, T.; Miller, W.; Nathan, P.; and Marlatt, G., eds. Addictive Behaviors: Prevention and Early Intervention. Amsterdam: Swets & Zeitlinger, 1989. pp. 219-231.
National Institute on Alcohol Abuse and Alcoholism. Eighth Special Report to the U.S. Congress on Alcohol and Health. 1993.
National Institute on Alcohol Abuse and Alcoholism. Assessing Alcohol Problems: A Guide for Clinicians and Researchers. Allen, J.P.; and Columbus, M., eds. NIAAA Treatment Handbook Series, Number 4. NIH Pub. No. 95-3745. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism. 1995a.
National Institute on Alcohol Abuse and Alcoholism. The Physicians' Guide to Helping Patients With Alcohol Problems. NIH Pub. No. 95-3769. Rockville, MD: National Institute on Alcohol Abuse and Alcoholism. 1995b.
National Institute on Drug Abuse. Recovery Training and Self-Help: Relapse Prevention and Aftercare for Drug Addicts. NIH Pub. No. 93-3521. Rockville, MD: National Institute on Drug Abuse. 1993.
National Institute on Drug Abuse. Assessing Drug Abuse Among Adolescents and Adults: Standardized Instruments. 1994.
National Institute on Drug Abuse. Drug Abuse and Drug Abuse Research: The Fifth Triennial Report to Congress. Rockville, MD: National Institute on Drug Abuse. 1996.
National Institute on Drug Abuse. Drug Abuse and Drug Abuse Research: The Fourth Triennial Report to Congress. Rockville, MD: National Institute on Drug Abuse, unpublished.
Newcomb, M.D. Identifying high-risk youth: Prevalence and patterns of adolescent drug abuse. In: Rahdert, E., and Czechowicz, D., eds. Adolescent Drug Abuse: Clinical Assessment and Therapeutic Interventions. NIDA Research Monograph Series, Number 156. NIH Pub. No. 95-3908. Rockville, MD: U.S. National Institute on Drug Abuse, 1995. pp. 7-38.
Newcomb, M.D., and Bentler, P.M. Consequences of Adolescent Drug Use. Newbury Park, CA: Sage Publications. 1988.
Ockene, J.K. Physician-delivered interventions for smoking cessation: Strategies for increasing effectiveness. Preventive Medicine. 1987;16:723-737.
Orford, J.; Oppenheimer, E.; and Edwards, G. Abstinence or control: The outcome for excessive drinkers two years after consultation. Behavior Research and Therapy. 1976;14:409-418.
Paperny, D.M.; Aono, J.Y.; Lehman, R.M.; Hammar, S.L.; and Risser, J. Computer-assisted detection and intervention in adolescent high-risk health behaviors. Journal of Pediatrics. 1990;116:456-462.
Persson, J., and Magnusson, P.H. Early intervention in patients with excessive consumption of alcohol: A controlled study. Alcohol. 1989;6:403-408.
Persson, J.; Magnusson, P.H.; and Borg, S. Serum gamma-glutamyl transferase (GGT) in a group of organized teetotalers. Alcohol. 1990;7(2):87-89. [pmid: 1970255].
Prochaska, J.O. Strong and weak principles for progressing from precontemplation to action on the basis of twelve problem behaviors. Health Psychology. 1994;13(1):47-51. [pmid: 8168471].
Prochaska, J.; DiClemente, C.; and Norcross, J. In search of how people change. American Psychologist. 1992;47(9):1102-1114. [pmid: 1329589].
Rahdert, E., ed. The Adolescent Assessment/Referral System Manual. 1991.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.J.; Judd, L.L.; and Goodwin, F.K. Comorbidity of mental disorders with alcohol and other drug abuse. Results from the Epidemiologic Catchment Area (ECA) Study. Journal of the American Medical Association. 1990;264(19):2511-2518. [pmid: 2232018].
Rice, D.P. The economic cost of alcohol abuse and dependence: 1990. Alcohol Health & Research World. 1993;17(1):10-11.
Rice, D.P.; Kelman, S.; Miller, L.S.; and Dunmeyer, S. The Economic Costs of Alcohol and Drug Abuse and Mental Illness: 1985. 1990.
Romelsjo, A.; Andersson, L.; Barrner, H.; Borg, S.; Granstrand, C.; Hultman, O.; Hassler, A.; Kallqvist, A.; Magnusson, P.; Morgell, R.; Nyman, K.; Olofsson, A.; Olsson, E.; Rhedin, A.; and Wikblad, O. A randomized study of secondary prevention of early stage problem drinkers in primary health care. British Journal of Addiction. 1989;84:1319-1327.
Rose, G., and Day, S. The population mean predicts the number of deviant individuals. British Medical Journal. 1990;301(6759):1031-1034. [pmid: 2249053].
Rosenberg, H.M.; Ventura, S.J.; Maurer, J.D.; Heuser, R.L.; and Freedman, M.A. Births and deaths: United States, 1995. Monthly Vital Statistics Report 45(3). 1996.
Rouse, B.A.; Carter, J.H.; and Rodriguez-Andrew, S. Racial ethnicity and other sociocultural influences on alcohol treatment for women. In: Galanter, M., ed. Recent Developments. Vol. 12, Alcohol and Women. New York: Plenum Press, 1995. pp. 343-367.
Russell, M. New assessment tools for risk drinking during pregnancy: T-ACE, TWEAK, and others. Alcohol Health and Research World. 1994;18(1):55-61.
Russell, M.A.; Wilson, C.; Taylor, C.; and Baker, C.D. Effect of general practitioners' advice against smoking. British Medical Journal. 1979;2:231-235.
Saitz, R.; Mulvey, K.P.; Plough, A.; and Samet, J.H. Physician unawareness of serious substance abuse. American Journal of Alcohol Abuse. in press.
Samet, J.H.; Pollnick, S.; and Barnes, H. Beyond CAGE: A brief clinical approach after detection of substance abuse. Archives of Internal Medicine. 1996;156:2287-2293.
Sanchez-Craig, M. Brief didactic treatment for alcohol and drug-related problems: An approach based on client choice. British Journal of Addiction. 1990;85:169-177.
Sanchez-Craig, M.; Leigh, G.; Spivak, K.; and Lei, H. Superior outcome of females over males after brief treatment for the reduction of heavy drinking. British Journal of Addiction. 1989;84:395-404.
Sannibale, C. The differential effect of a set of brief interventions on the functioning of a group of "early stage" problem drinkers. Australian Drug and Alcohol Review. 1988;7:147-155.
Saunders, J.B.; Aasland, O.G.; Babor, T.F.; de la Fuente, J.R.; and Grant, M. Development of the Alcohol Use Disorders Identification Test (AUDIT): WHO collaborative project on early detection of persons with harmful alcohol consumption-II. Addiction. 1993;88:791-804.
Schnoll, S.H., and Daghestani, A.N. Treatment of marijuana abuse. Psychiatric Annals. 1986;16(4):249-254.
Schuckit, M.A. Goals of treatment. In: Galanter, M., and Kleber, H.D. The American Psychiatric Press Textbook of Substance Abuse Treatment. Washington, DC: American Psychiatric Press, 1994. pp. 3-10.
Schuckit, M.A., and Irwin, M. Diagnosis of alcoholism. Medical Clinics of North America. 1988;72:1133-1153.
Scott, E., and Anderson, P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug and Alcohol Review. 1990;10:311-322.
Seale, J.P., and Muramoto, M.L. Substance abuse among minority populations. Substance Abuse. 1993;20(1):167-180.
Selzer, M.L. The Michigan Alcoholism Screening Test: The quest for a new diagnostic instrument. American Journal of Psychiatry. 1971;127:165658.
Selzer, M.L.; Vinokur, A.; and Van Rooijen, L. A self-administered Short Michigan Alcoholism Screening Test (SMAST). Journal of Studies on Alcohol. 1975;36:117-126.
Skinner, H.A. Benefits of sequential assessment. Social Work Research and Abstracts. 1981;17:21-28.
Skinner, H.A. Alcohol/drug problems in primary care: Changing roles—changing practices. In: Proceedings of the Secretarial Conference To Link Primary Care, HIV, Alcohol and Drug Treatments. Washington, DC, February 26-28, 1992.
Skinner, H.A., and Allen, B.A. Alcohol dependence syndrome: Measurement and validation. Journal of Abnormal Psychology. 1982;91:199-209.
Skinner, H.A.; Allen, B.A.; McIntosh, M.C.; and Palmer, W.H. Lifestyle assessment: Just asking makes a difference. British Medical Journal. 1985;290:214-216.
Skinner, H.A.; Holt, S.; Schuller, R.; Roy, J.; and Israel, Y. Identification of alcohol abuse using laboratory tests and a history of trauma. Annals of Internal Medicine. 1984;101(6):847-851. [pmid: 6149716].
Smith, D.E.; Buxton, M.E.; Bilal, R.; and Seymour, R.B. Cultural points of resistance to the 12-Step recovery process. Journal of Psychoactive Drugs. 1993;25(1):97-108. [pmid: 8483054].
Smith, M.B.; Hoffmann, N.G.; and Nederhoed, R. The development and reliability of the Recovery Attitude and Treatment Evaluator—Questionnaire I (RAATE-QI). The International Journal of the Addictions. 1995;30:147-160.
Sobell, L.C.; Sobell, M.B.; Toneatto, T.; and Leo, G.I. What triggers the resolution of alcohol problems without treatment. Alcoholism: Clinical and Experimental Research. 1993;17(2):217-224.
Spector, R. 1996.
Spitzer, R.L.; Williams, J.B.W.; Kroenke, K.; Linzer, M.; deGruy, F.V. III; Hahn, S.R.; Brody, D.; and Johnson, J.G. 1994.
Steinweg, D.L., and Worth, H. Alcoholism:CAGE1993
Stinson, F.S.; Dufour, M.C.; Steffens, R.A.; and DeBakey, S.F. 1993.
Substance Abuse and Mental Health Services Administration. Percent of population with substance abuse, mental disorder, or both disorders in lifetime, age 15 to 54, 1991. In: Rouse, B.A., ed. Substance Abuse and Mental Health Statistics Sourcebook. DHHS Pub. No. (SMA) 95-3064. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1995. p. 37.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. Annual Trends in Prescription and Over-the-Counter Drug-Related Episodes. Preliminary Estimates From the Drug Abuse Warning Network. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996a. http://www.health.org/pubs/96dawn/ar17g.htm [Accessed Oct 29, 1996].
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. Any illicit drug use. In: National Household Survey on Drug Abuse Advance Report No. 18. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1996b. http://www.samhsa.gov/oas/nhsda/ar18t013.htm#A1 [Accessed Oct 29, 1996].
Sullivan, E.J., ed. Nursing Care of Clients With Substance Abuse. St. Louis: Mosby. 1995.
Sullivan, E.J.; Bissell, L.; and Leffler, D. Drug and disciplinary actions among 300 nurses. International Journal of the Addictions. 1990;25(4):375-391. [pmid: 2246088].
Sullivan, E.J.; Bissell, L.; and Williams, E. Chemical Dependency in Nursing: The Deadly Diversion. Menlo Park, CA: Addison-Wesley. 1988.
Sullivan, J.T.; Sykora, K.; Schneiderman, J.; Naranjo, C.A.; and Sellers, E.M. Assessment of alcohol withdrawal: The revised Clinical Institute Withdrawal Assessment for Alcohol scale (CIWA-Ar). British Journal of Addiction. 1989;84:1353-1357.
Swenson, W.M., and Morse, R.M. The use of a self-administered alcoholism screening test (SAAST) in a medical center. Mayo Clinic Proceedings. 1975;50:204-208.
Tolley, K., and Rowland, N. Identification of alcohol-related problems in a general hospital setting: A cost-effectiveness evaluation. British Journal of Addiction. 1991;86(4):429-438. [pmid: 1905168].
Trimble, J.E.; Bolek, C.S.; and Niemeryk, S.J., eds. Ethnic and Multicultural Drug Abuse. Perspectives on Current Research. Part I. New York: Haworth Press. 1992.
U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Baltimore, MD: Williams & Wilkens. 1996.
Vaillant, G.E.; Clark, W.; Cyrus, C.; Milofsky, E.S.; Kopp, J.; Wulsin, V.W.; and Mogielnicki, N.P. Prospective study of alcoholism treatment. Eight-year follow-up. American Journal of Medicine. 1983;75:455-460.
Velicer, W.F.; Hughes, S.L.; Fava, J.L.; Prochaska, J.O.; and DiClemente, C.C. An empirical typology of subjects within stage of change. Addictive Behavior. 1995;20(3):299-320.
Wallace, B. Crack-Cocaine: A Practical Treatment for the Chemically Dependent. New York, NY: Bruner/Mazel. 1991.
Wallace, P.; Cutler, S.; and Haines, A. A randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. British Medical Journal. 1988;297:663-668.
WHO Brief Intervention Study Group. A cross-national trial of brief interventions with heavy drinkers. American Journal of Public Health. 1996;86(7):948-955. [pmid: 8669518].
Wilson, D.M.; Taylor, W.; Gilbert, J.R.; Best, J.A.; Lindsay, E.A.; Willms, D.G.; and Singer, J. A randomized trial of a family physician intervention for smoking cessation. . Journal of the American Medical Association. 1988;260:1570-1574.
Yano, E.M.; Fink, A.; Hirsch, S.H.; Robbins, A.S.; and Rubenstein, L.V. Helping practices reach primary care goals: Lessons from the literature. Archives of Internal Medicine. 1995;155:1146-1156.
Yokel, R.A. Intravenous self-administration: Response rates, the effects of pharmacological challenges, and drug challenges. In: Bozarth, M.A., ed. Methods of Assessing the Reinforcing Properties of Abused Drugs. New York: Springer-Verlag, 1987. pp. 1-33.
Zador, P.L. Alcohol-related relative risk of fatal driver injuries in relation to driver age and sex. Journal of Studies on Alcohol. 1991;52:302-310.