# Appendix G—Field Reviewers

- Catherine Adams
- Professor
- Department of Nursing
- The Sage Colleges
- Troy, New York

- Kristen Barry, Ph.D.
- Associate Research Scientist
- Serious Mental Illness Treatment Research and Evaluation Center
- Veterans Administration
- Ann Arbor, Michigan

- Robert Bick, M.A., S.A.C.
- Director
- Champlain Drug and Alcohol Services
- Howard Center for Human Services
- South Burlington, Vermont

- Richard L. Brown, M.D., M.P.H.
- Assistant Professor
- Department of Family Medicine
- University of Wisconsin School of Medicine
- Madison, Wisconsin

- James Carter, M.D.
- Professor
- Department of Psychiatry
- Duke University Medical Center
- Durham, North Carolina

- Imodale L. Caulker-Burnett, R.N., C.-F.N.P., M.A.
- Family Nurse Practitioner
- Substance Abuse Consult Service
- Division of Substance Abuse Medicine
- Medical College of Virginia Hospitals
- Richmond, Virginia

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical/Professional Affairs
- Treatment Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Sara S. DeHart, Ph.D., R.N.
- Associate Professor
- School of Nursing
- University of Minnesota
- Minneapolis, Minnesota

- Martin C. Doot, M.D.
- Chief
- Division of Addiction Medicine
- Addiction Medicine/Family Practice
- Lutheran General Hospital Advocate
- Park Ridge, Illinois

- John Fitzpatrick, Ph.D.
- Director
- Alcoholism Program
- Sunset Terrace Family Health Center
- Brooklyn, New York

- Linda S. Foley, M.A.
- Member
- TIPS Editorial Advisory Board
- Chevy Chase, Maryland

- Karen M. Goans, C.C.D.C.
- Clinical Supervisor
- Addictive and Mental Disorders Center
- Montana Chemical Dependency Center
- Butte, Montana

- Norman Graham, Ph.D.
- Manager
- Family and Behavioral Health
- Metro Health Clement Center
- Cleveland, Ohio

- Allan Graham, M.D.
- Associate Medical Director
- Chemical Dependency Treatment Services
- Kaiser Permanente
- Denver, Colorado

- Sandra Handley, Ph.D., R.N., C.A.R.N.
- Consultant
- Addiction Training Center
- University of Missouri-Kansas City
- Kansas City, Missouri

- Harry W. Haverkos, M.D.
- Director
- Office on AIDS
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Lt. Col. Kenneth J. Hoffman, M.D., M.P.H., M.C.F.S.
- Director, Center for Addiction Medicine
- Center for Training and Education in
- Addiction Medicine (C-Team)
- Department of Preventive Medicine/Biometrics
- Uniformed Services University of the Health Sciences
- Bethesda, Maryland

- Robert Holden, M.A.
- Program Director
- Partners in Drug Abuse Rehabilitation Counseling
- Washington, D.C.

- Deborah Horan
- Manager
- Special Issues
- American College of Obstetrics and Gynecology
- Washington, D.C.

- Vaughn J. Howland
- Director
- The Intervention Center
- Kensington, Maryland

- Christine Kasser, M.D.
- Assistant Professor and Medical Director
- Recovery Services
- Behavioral Health Center
- College of Medicine
- University of Tennessee at Memphis
- Memphis, Tennessee

- Julian F. Keith, M.D.
- Director
- Developmental Disabilities and Substance Abuse Services
- Division of Mental Health
- Department of Human Resources
- Raleigh, North Carolina

- Anton J. Kuzel, M.D.
- Associate Professor
- Director of Graduate Programs
- Medical College of Virginia
- Richmond, Virginia

- Geoffrey Laredo
- Office of Policy Analysis
- National Institute on Alcohol Abuse and Alcoholism
- Kensington, Maryland

- Stephen W. Long
- Director
- Office of Policy Analysis
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Kathleen Masis, M.D.
- Medical Officer for Chemical Dependency
- Office of Health Care
- Billings Area Indian Health Service
- Billings, Montana

- Daniel Nauts, M.D.
- Medicaid Director
- Addiction Medicine Center
- Behavioral Health Services
- Benefits Health Care
- Great Falls, Montana

- Christine D. Olson, M.S.
- Director
- Services for Families, Women, and Children
- Colorado Alcohol and Drug Abuse Division
- Denver, Colorado

- Paula Ortiz Smith, L.M.S.W.
- Social Services Coordinator
- Ben Archer Health Center
- Hatch, New Mexico

- Gennaro Ottomanelli, Ph.D.
- Director
- Division of Drug Dependence
- Kings County Addictive Disease Hospital
- Brooklyn, New York

- Anthony Quintiliani, Ph.D.
- Clinical Director, Chief Psychologist
- Drug and Alcohol Division
- Howard Center for Human Services
- Burlington, Vermont

- Anthony Radcliffe, M.D.
- Regional Coordinating Chief of Addiction Medicine
- Kaiser Permanente/CDRP
- Fontana, California

- Barbara Reid, M.S.W.
- Social Worker
- Ann Arbor, Michigan

- Peter B. Rockholz, M.S.S.W.
- Director
- APT Residential Services
- APT Foundation
- Newtown, Connecticut

- June Ross, B.S., I.C.A.D.C.
- Executive Director
- 12 & 12, Inc.
- Tulsa, Oklahoma

- Linda S. Ruble, P.A./C.
- Administrative Director
- Primary Health Care, Inc.
- Broadlawns Medical Center
- Des Moines, Iowa

- Richard Saitz, M.D., M.P.H.
- Assistant Professor of Medicine
- Clinical Addictions Research and Education Unit
- Section of General Intense Medicine
- Boston Medical Center
- Boston, Massachusetts

- Margaret Salinger, M.S.N., R.N., C.A.R.N.
- National Nurses Society on Addiction
- c/o Department of Veterans Affairs Medical Center
- Coatesville, Pennsylvania

- Eleanor Sargent
- Director, Clinical Issues
- The National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- William Schlenger, Ph.D.
- Director
- Mental and Behavioral Health Research
- Health and Social Policy Division
- Research Triangle Institute
- Research Triangle Park, North Carolina

- Lynn Shelton
- President
- Shelton Consulting
- El Paso, Texas

- James E. Smith, Ph.D
- Professor and Chair
- Department of Physiology/Pharmacology
- Bowman Gray School of Medicine
- Winston-Salem, North Carolina

- Mary Jo Stralka, Ph.D., C.P.N.P.
- Associate Clinical Professor
- Barnes College of Nursing
- University of Missouri at St. Louis
- St. Louis, Missouri

- Richard T. Suchinsky, M.D.
- Associate Director
- Addictive Disorders
- Mental Health and Behavioral Sciences Services
- Department of Veterans Affairs
- Washington, D.C.

- John M. Thorp, Jr., M.D.
- Associate Professor
- School of Medicine
- University of North Carolina at Chapel Hill
- Chapel Hill, North Carolina

- Jeanne G. Trumble, M.S.W.
- Executive Director
- American Academy of Addiction Psychiatry
- Prairie Village, Kansas

- Mark Werner, M.D.
- Associate Professor and Director
- Division of Adolescent Medicine
- School of Medicine
- Vanderbilt University
- Nashville, Tennessee

- Joyce Young, M.D., M.P.H
- Medical Director
- Research Triangle Park
- IBM
- Research Triangle Park, North Carolina