# Appendix F—Resource Panel

- M. Carolyn Aoyama, C.N.M., M.P.H.
- Deputy Chief
- Clinical Branch
- Bureau of Primary Health Care
- U.S. Public Health Service
- Division of Community and Migrant Health
- Bethesda, Maryland

- Adrienne W. Askew
- Student Representative
- Commission on Public Health
- American Academy of Family Physicians
- Washington, D.C.

- Juliann DeStefano
- Special Assistant
- Office of the Director
- Center for Mental Health Services
- Rockville, Maryland

- James V. Dolson
- Child and Family Development
- Office of Planning, Research, and Evaluation
- Administration for Children and Families
- Washington, D.C.

- Jean Donaldson
- Public Health Advisor
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Linda S. Foley, M.A.
- Member
- TIPS Editorial Advisory Board
- Chevy Chase, Maryland

- Harry W. Haverkos, M.D.
- Director
- Office on AIDS
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Vaughn J. Howland
- Director
- The Intervention Center
- Kensington, Maryland

- Howard Lerner, M.P.H.
- Deputy Director
- Division of Special Populations
- Bureau of Primary Health Care
- Health Resources and Services Administration
- Bethesda, Maryland

- Sloan Mahone
- Deputy Director of Research
- American Academy of Child and Adolescent Psychiatry
- Washington, D.C.

- Mary Kay Mullen
- Health Insurance Specialist
- Medicaid Bureau
- Health Care Financial Administration
- Baltimore, Maryland

- David C. Thompson
- Public Health Advisor
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Verna Tyler
- Health Insurance Specialist
- Medicaid Bureau
- Health Care Financial Administration
- Baltimore, Maryland