# Appendix D—Substance Abuse Resources for the Primary Care Setting

- Alcoholics Anonymous
- P.O. Box 459
- Grand Central Station
- New York, NY 10163
- (212) 870-3400

- http://www.alcoholics-anonymous.org/index.html (general)
- http://www.alcoholics-anonymous.org/pro/engpro.html (information for professionals)

Single copies of the following pamphlets are free to those with a professional interest in Alcoholics Anonymous:

- Alcoholics Anonymous as a Resource for the Medical Profession
- The Alcoholics Anonymous Member -- Medications and Other Drugs

- Hazelden
- CO.3, P.O. Box 11
- Center City, MN 55012-0011
- (800) 257-7810

- http://www.hazelden.org/index.dbm

Low-cost information available on subjects such as

- Alcoholism and other drug addictions
- Family and friends' addiction issues
- Psychiatric problems with alcoholism/drug addition
- Special populations

- National Clearinghouse for Alcohol and Drug Information
- (800) 729-6686
- (301) 468-6433 fax

Free publications include

Tips for Teens

- Tips for Teens About Alcohol (PH323)

Prevention Program Planners

- Making the Link Fact Sheets (Center for Substance Abuse Prevention, 1994)

These one-page fact sheets discuss alcohol and other drug abuse in various settings such as the workplace and college and examine substance abuse's relationship to societal problems such as violence and automobile crashes.

Women

- Healthy Women/Healthy Lifestyles: Here's What You Should Know About Alcohol, Tobacco, and Other Drugs (Center for Substance Abuse Prevention, 1995)

This eight-page, two-color brochure examines why women are at especially high risk for the health and social problems caused by substance abuse. The booklet describes how alcohol affects women and men differently physiologically and why pregnant women shouldn't drink, smoke, or take illicit drugs. The links between violence and child abuse and neglect and substance abuse are also examined. A list of organizations that provide help are given on the last page. (PHD691)

- Women and Drug Abuse * (National Institute on Drug Abuse, 1994)

This brochure addresses issues of particular importance to drug-abusing women: HIV/AIDS and maternal exposure to drugs. Encourages women, their families, and friends to seek treatment for drug addiction and provides information on where to go for help. (PHD669)

Alcohol Alert (Publications in Series)

- Alcohol and AIDS #15 (PH311) (http://www.niaaa.nih.gov/publications/aa15.htm)
- Moderate Drinking #16 (PH315) (http://www.niaaa.nih.gov/publications/aa16.htm)
- Alcohol and the Liver #19 (PH329) (http://www.niaaa.nih.gov/publications/aa19.htm)
- Alcohol and Cancer #21 (PH345) (http://www.niaaa.nih.gov/publications/aa21.htm)
- Alcohol and Nutrition #22 (PH346) (http://www.niaaa.nih.gov/publications/aa22.htm)
- Alcohol and Minorities #23 (PH347) (http://www.niaaa.nih.gov/publications/aa23.htm)
- Alcohol-Related Impairment #25 (PH351) (http://www.niaaa.nih.gov/publications/aa25.htm)
- Alcohol and Hormones #26 (PH352) (http://www.niaaa.nih.gov/publications/aa26.htm)
- Alcohol Medication Interactions #27 (PH355) (http://www.niaaa.nih.gov/publications/aa27.htm)

Patient Education Materials for Health Professionals

These can be ordered in bulk for waiting rooms. Titles include

- How Getting High Can Get You AIDS (PHD573)
- If You Use Steroids, These Aren't the Only Things Stacked Against You (PHD624)

See catalog for additional titles.

- National Council on Alcoholism and Drug Dependence, Inc. (NCADD)
- 12 West 21st Street
- New York, NY 10010
- (212) 206-6770
- (212) 645-1690 fax
- Hope Line: (800) NCA-CALL
- Drug-specific information: (800) 729-6686
- http://www.ncadd.org/

Low-cost fact sheets and brochures include

- Alcohol-Related Birth Defects (revised 1994)
- Alcoholism and Alcohol-Related Problems (revised 1995)