# Consensus Panel

- Susan J. Brannen, M.A.
- Executive Director
- Pre-Trial Services Corporation of the Monroe County Bar Association
- Rochester, NY

- Alan Burden, M.Ed., L.P.C. - Facilitator
- Program Manager
- Clackamas County Mental Health Substance Abuse Program
- Milwaukie, OR

- Martha J. Castaneda, M.S.W.
- Clinical Supervisor
- Tucson AIDS Project (TAP)
- Tucson, AZ

- M. Denis Ferguson, M.A.
- Program Manager, Substance Abuse Services
- DuPage County Health Department

- James D. Gingerich
- Director
- Administrative Office of the Courts
- Justice Building, State Capitol
- Little Rock, AR

- John S. Goldkamp, Ph.D. - Facilitator
- President
- Crime and Justice Research Institute
- Philadelphia, PA

- Barry Mahoney, LL.B., Ph.D. - Co-Chair
- President
- The Justice Management Institute
- Denver, CO

- The Honorable Tomar Mason - Facilitator
- San Francisco Municipal Court
- San Francisco, CA

- Robert L. May II
- Executive Director
- National Consortium of TASC Programs
- Washington, DC

- E. Michael McCann, J.D.
- Milwaukee County District Attorney
- Milwaukee, WI

- Melody M. McEntee, M.S.W.
- Executive Assistant for Treatment Services
- Governor's Drug & Alcohol Abuse Commission
- Towson, MD

- Timothy J. Murray
- Director
- Metro Dade Office of Substance Abuse Control
- Miami, FL

- Carla J. Noto, M.A., LMFCC
- Clinical Supervisor/Programs Coordinator
- Santa Clara County Bureau of Alcohol and Drug Programs
- Felton, CA

- Kevin M. Sherin, M.D., M.P.H.- Co-Chair
- Program Director, Family Practice Residency
- Christ Hospital and Medical Center, Advocate Health Systems
- Oak Lawn, IL

- Shirley Thornton-Johnson, Ed.D.
- Director of Program Development
- Comprehensive Health Centers
- San Diego, CA

- The Honorable Jamey H. Weitzman
- The District Court of Maryland for Baltimore City
- Baltimore, MD

- Bob Wessels
- Court Manager
- Harris County Criminal Courts at Law
- Houston, TX

The Consensus Panel met in May 1994.