# Chapter 6—Program Evaluation

Program evaluation should be a process, not a one-time event, that begins before the startup of a program. The evaluator should be selected and the evaluation design developed while the program is in the design stage; that allows the evaluator and the program planners to jointly address key evaluation issues, for example, the articulation of program goals and the identification of appropriate performance measures, before implementation begins. The collaborative process, with ongoing communication and exchange of information, should then continue through the life of the program.

In the real world, arrangements for evaluation often fall short of the ideal. All too often, evaluators come into the picture only when implementation is about to begin or, worse, after it is well under way. The earlier evaluators are brought into the planning and program design process, the better.

This chapter is not a detailed guide to evaluation strategies and methods. Rather, it is an overview of ways to evaluate programs that integrate substance abuse treatment with the pretrial processing of criminal cases. The following topics are covered in a broad-brush fashion:

- Process evaluations
- Outcome evaluations
- Cost-benefit analyses
- Selection of an evaluator
- Funding for an evaluation.

## Process Evaluations

Process evaluations answer questions about how well a program is meeting administrative and procedural goals and should generate valuable information about program structure and operations. Questions typically addressed in a thorough process evaluation include the following:

How well is the program achieving its goals in terms of provision of services?

- To what extent is it reaching the intended target population? If the target group is not being reached, why not?
- What services (such as detoxification, assessment, treatment, and aftercare services) are being provided? To which program participants?
- What services not currently provided should be added? What current services should be dropped or modified? Why?
- What problems have been encountered in program implementation? To what extent, and how, have the problems been overcome?

Ideally, program evaluation will begin before program startup, with an evaluator selected and an evaluation design developed while the program is in the design stage.

What are the characteristics of the defendants participating in the program?

- To what extent, and in what ways, do the characteristics of participants differ from what was anticipated during the program design stage?
- What are the principal treatment and ancillary service needs of participants?
- Do program services reflect the needs of participants?
- Does the program provide culturally appropriate services and staff to address the needs of participants?
- Does the program provide treatment services and settings that can adequately address the needs of the full range of participants?

How does the program affect the work of courts, and other justice system agencies, and the overall delivery of substance abuse treatment?

- How do program operations affect caseloads and resource allocation in the court?
- How do program operations affect the delivery of treatment services to clients not involved in criminal cases?
- What are the attitudes and perceptions of justice system leaders and key practitioners?
- What are the attitudes and perceptions of treatment providers and public health officials?
- What are the attitudes of community leaders?
- How do key stakeholders in the jurisdiction perceive the effectiveness and value of the program?

Process evaluations will typically use information from a wide range of sources. The purposes are principally to describe and analyze actual operations in comparison to initial plans and to identify key implementation issues for review by program managers and key stakeholders. The primary audience for a process evaluation should be the program managers and key stakeholders in the jurisdiction, but good process evaluations should also be of interest to policymakers and practitioners in other jurisdictions that are considering program replication or adaptation. They can also be valuable in describing the context or environment in which program outcomes take place, and in that sense are closely related to outcome evaluations.

## Outcome Evaluations

Outcome evaluations focus on the goals of the program, both in terms of its impact on individuals and its impact on collaborating systems and the larger community. For example, if the program adapted goals similar to those outlined in Chapter 2, the evaluation design would attempt to measure success (or at least progress) in relation to those goals.

### Experimental Designs

Experimental designs are the preferred method for outcome evaluations. Using an experimental design, defendants would be assigned to one of two groups: (1) an experimental group that participates in the full range of program activities and is eligible for all services; or (2) a control group that does not receive program services or receives only the services that were available before implementation of the program. The principal advantage of experimental designs is that a relatively high degree of confidence can be placed in findings of differences in outcomes between the two groups.

It is not always feasible, however, to use an experimental design. First, experimental designs that minimize possible "contamination" of the experiment can be expensive. Second, they may not be ethical or legal. For example, a judge, prosecutor, or defense attorney may object to random assignment of defendants to services, arguing that it is unfair or a denial of equal protection of law to arbitrarily withhold beneficial program services from eligible defendants who have a demonstrated need for treatment.

One strategy that has been used to allay concerns related to defendants' need for, or rights to, treatment is to assign defendants to one of several different "categories" of treatment. For example, defendants might be randomly assigned to a more intensive group (daily outpatient groups, drug education, and drug testing), or to a less intensive group (only drug education and drug testing). This strategy ensures that all defendants identified as needing substance abuse treatment receive some services. Experimental designs are generally more tenable when defendants are not ordered by the court to participate in the program and when defendants provide a full and informed consent regarding their involvement in randomization procedures and other program evaluation activities. Evaluation procedures, including legal and ethical issues, should be carefully reviewed by judges, prosecutors, and defense attorneys before an experimental evaluation design is implemented.

### Quasi-Experimental Designs

If an experimental design is inappropriate, for whatever reason, a second approach is to develop a quasi-experimental design that allows for scientifically rigorous examination of outcomes. One type of quasi-experimental evaluation is a pre-post design, in which outcomes obtained following discharge from a drug court program are compared to those obtained prior to program participation. For example, defendants' frequency of drug use, frequency of arrests, or length of time between arrests can be compared before and after admission to the program. A drawback to pre-post designs is that they do not take into account other factors that may contribute to the behavior changes they measure. For example, a reduction in drug use among program participants might be influenced by a sudden decrease in the supply of drugs in a community. Using a pre-post design, this reduction might mistakenly be attributed to involvement in treatment. In contrast, an experimental design would demonstrate reductions in drug use among both the "treatment" and "no-treatment" groups, making it clear what effects on drug use were attributable to the program.

Another type of quasi-experimental evaluation studies one or more comparison groups, rather than a randomly assigned control group. Using this design, results from the experimental and comparison groups are contrasted. Comparison groups consist of substance-abusing defendants who do not participate in (or who do not complete) the drug court program. These groups should include defendants who have substance abuse problems and who are otherwise similar to program participants in key areas such as criminal history, severity of most recent offense, age, gender, ethnicity, substance abuse history, employment, income, and other areas used as eligibility criteria in the program. It is often useful to "match" subjects in experimental and comparison groups to control for the problem of confounding variables introduced through nonrandom assignment. Using this approach, both groups' subjects are selected based on factors expected to affect outcomes, such as age or educational attainment.

One useful type of comparison group consists of defendants placed on a program "waiting list." Use of such a group minimizes differences in motivation for treatment and other potential differences in program eligibility that may affect evaluation outcomes. Other comparison groups could include: (1) defendants who are eligible for the program but elect not to participate; (2) defendants who are discharged from the program prior to completion; and (3) other groups of defendants who are similar to program participants in the areas described above.

Process evaluations answer questions about how well a program is meeting administrative and procedural goals. Outcome evaluations focus on the goals of the program, both in terms of its impact on individuals and its impact on collaborating systems and the larger community.

## Cost-Benefit Analysis

In an era of fiscal restraint and close scrutiny of social services programs, program leaders should expect evaluators to study the costs and benefits of a program integrating substance abuse treatment with pretrial case processing. Cost-benefit analysis builds upon both process and outcome evaluations. The cost side of the study requires a good understanding of the program's operating procedures and of the actual costs of those operations for all the participating organizations. The benefits are the positive outcomes sought by the program.

Cost-benefit evaluation strategies focus on the economic impacts of substance abuse treatment before and after involvement in the program. Cost-benefit analysis must build on a solid foundation of knowledge about program operations, impact, and costs of the program as well as criminal justice, health care, and labor market operations and costs. Such analysis requires time (for follow-up on participants' post-program behavior), specialized expertise in justice system and health care operations and economics, and money to support the research. See Chapter 7 for an example of a cost-benefit analysis.

## Selecting an Evaluator

Evaluations are usually conducted by an outside or "independent" evaluator -- an individual or group that has no affiliation with the organizations involved in the program, and is thus less likely to have a conflict of interest or bias about the merits of the program. However, it is possible to have objective "internal" evaluations, and in some jurisdictions there are criminal justice agencies that have highly competent in-house research departments capable of evaluating the program.

Regardless of whether evaluators are external or internal, they must have experience conducting evaluations. Ideally, the evaluator will be knowledgeable about both justice system operations and substance abuse treatment. If a potential evaluator has experience with criminal justice operations but not with substance abuse treatment, or vice versa, the evaluator should be involved early, while the program is still in the planning and design stages, if possible.

The evaluator should be someone in whom the program team has confidence, because trust and open communications are important elements of a good evaluation. The evaluator should be willing to develop strategies that address questions important to program managers and key stakeholders and to regularly update program staff on preliminary findings from the evaluation. The evaluator will need full access to program records and to management information reports and other documents relevant to program operations and will need to be able to interview program staff, clients, and policymakers. There should be full agreement between the evaluator and the program leaders from the outset, preferably, before initial implementation of the program, on the goals and objectives of the program and of the evaluation, on the performance measures and evaluation methods to be used, and on the procedures, costs, timelines, and report review procedures to be followed. The agreement can be formalized in a contract.

Regardless of whether evaluators are external or internal, it is critically important for them to have experience conducting evaluations. Ideally, they will be knowledgeable about both justice system operations and substance abuse treatment.

## Funding for an Evaluation

The scope, focus, and depth of an evaluation will necessarily be limited by the funds available. Using a very rough rule of thumb, evaluation is sometimes budgeted at 5-15 percent of the overall program budget, but the percentage actually spent varies considerably depending on the circumstances (and the degree of interest the policymakers and program managers have in evaluation of the program). Regardless of the amount of funds available, close attention should be paid to evaluation priorities and strategies. The following are some key questions to be asked, by both the evaluator and the program leaders, in developing evaluation priorities and strategies:

What are the most important things to know about the program in terms of operations and/or impact?

- What data are needed to answer these questions?
- What relevant information is already available?
- Given available resources, what additional data can be collected and, together with data already available, analyzed to produce answers to the top priority questions?
- How will preliminary findings be presented and reviewed, with opportunity for input from the program team and key stakeholders, before submission of a formal report?
- How can the evaluation findings be used? How can a focus on these questions, using these research techniques, help shape program policy and practice?

A range of local, State, Federal and private resources may be available to help support evaluations of drug court programs. If funding is limited, assistance from colleges and universities may be sought. Often, they have social science departments looking for places to conduct evaluation and research.