# Chapter 5—Implementation

Implementation of a program that integrates substance abuse treatment with pretrial case processing tests the soundness of all the preliminary decisions and requires the continued support of those who planned and designed it. No matter how careful the planning and how sound the program design on paper, actual implementation will require some adjustments. Implementing a drug court means change:

- Changing operating procedures in the court and other agencies involved in the program
- Changing the philosophies that underlie the day-to-day activities of the participating agencies, especially emphasizing the individual defendant's potential for rehabilitation through treatment
- Establishing new working relationships, especially those between substance abuse treatment personnel and criminal justice practitioners
- Identifying new roles for both the justice system and treatment practitioners, especially the judges, prosecutors, and defense lawyers handling cases involving substance-abusing offenders who are admitted to the program.

This chapter discusses eight major implementation issues:

- Personnel selection
- Facilities and transportation
- Education and training
- Startup operations
- Ongoing operations
- Case management
- Program organization and management
- Feedback mechanisms and program adjustments.

## Personnel Selection

Perhaps the most critical decisions in program implementation are those concerning personnel. Often, many of the decisions about personnel will have been made before the implementation stage, and some key members of the program team will have been involved in the initial planning and program design phases. If so, they will be familiar with the program's goals and planned operating procedures and will have established working relationships with others involved in the program. If not, or if only some members of the program team have been involved in planning and design, then selection of additional members of the team is extremely important for implementation.

Selection of personnel for the program team is complicated by the fact that team members are drawn from different institutions and agencies. Selection of team members is generally not done by a single "program director" but rather by the leaders of the institutions and agencies involved in the program. For example, the judge or judges are often designated by the chief judge of the court; the prosecutor or a senior deputy will select the assistant prosecutor(s) who will work with the team; and the public defender will select the assistant public defender.

It is highly desirable to begin program implementation with staff who, regardless of organizational affiliation, are convinced of the need for and effectiveness of substance abuse treatment for criminal justice populations. When key stakeholders such as the chief judge of the court, the prosecutor, and the public defender have been involved in the planning and design activities, the likelihood of having committed staff members assigned to the program is greatly enhanced.

As noted in Chapter 4, a typical interdisciplinary team includes a judge, prosecutor, defense attorney, screening officer, court clerk or coordinator, assessment officer, case manager, and treatment program liaison officer. It is important to recognize that, although many of the functions performed by these individuals will be new, the positions are not necessarily additions to the existing judicial and agency staff personnel rosters. Rather, because the new program involves cases that would be handled by the court in any event, judges and staff for the program can often be found by reorganizing workflow and revising personnel assignments.

## Facilities and Transportation

Optimally, the court will have facilities for assessment and treatment in close proximity to the court. In Little Rock, Arkansas, for example, a substance abuse assessment unit, public health provider, treatment program, and court are all located in one building. In Washington, D.C., where urine screening is a major part of the drug court program, the D.C. Pretrial Services Agency has drug-testing facilities in the courthouse.

When assessment, drug testing, and treatment facilities are not located in or near the courthouse, it is helpful to develop transportation links between the court and the treatment providers. This is especially important during the early stages of a defendant's participation in the program when the defendant may not yet be totally committed to treatment.

In Miami, the court has a van that transports participating defendants directly from court to the treatment facility following the court proceeding at which the defendant was admitted to the program.

## Education and Training

One of the clear lessons learned from attempts to introduce major innovations in American courts is that a significant amount of time and energy must be invested in education and training both before and during program implementation. The formal integration of substance abuse treatment and pretrial case processing on a large scale is a relatively new concept in the United States. Those working in a collaborative program involving the justice system and the treatment community must be educated about the underlying concepts and, in some instances, trained to perform new functions.

Education about a program involving the integration of substance abuse treatment and pretrial case processing should focus on

- The purpose of criminal case processing and substance abuse treatment
- The concept of integration of substance abuse treatment and pretrial case processing
- The reasons why the program is being undertaken
- The goals and potential benefits of the program
- The types of cases that will be "targeted" for admission to the program and the reasons for focusing on these case categories
- How the program works operationally and how this differs from current practices, with particular attention to
  - Immediacy of action, rapid screening of cases, and action focused on entry into the program shortly after arrest
  - Ongoing case supervision by the judge focused on the defendant's progress in treatment
  - Open and timely exchange of information concerning individual cases among the court, other justice system agencies, the treatment provider(s), and public health agencies
  - Policies toward defendant "relapses" that incorporate graduated sanctions and that rewards for progress in refraining from substance abuse.

Potential audiences for educational efforts focused on program implementation include

- Justice system, treatment community, and public health system administrators and supervisors
- Criminal justice practitioners who handle cases involving defendants potentially eligible for the program, including
  - Judges
  - Prosecutors
  - Defense lawyers
  - Courtroom clerks/program coordinators
  - Pretrial services and Treatment Alternatives to Street Crime (TASC) program staff members
  - Probation and community corrections department staff members
  - Law enforcement personnel.
- Substance abuse treatment staff members at all levels
- Bar and business leaders
- Legislative and executive branch officials at the municipal, county, and State levels
- Officials and senior staff members in agencies that can provide needed ancillary services (such as hospitals, other health care service providers, schools, and employment services)
- The media
- Community groups interested in criminal justice and substance abuse issues.

The approaches to educating members of these groups will vary from jurisdiction to jurisdiction, and by audience. To a significant extent, education about the program will take place during the planning and program design stages, as members of the planning group become familiar with basic concepts and with information on similar programs in other jurisdictions. Once the detailed program design has been developed and before full-scale implementation, concentrated efforts should be devoted to education directed at the audiences listed above and any others the planning team identifies as relevant to the program's operation. Job-focused training should be provided for the practitioners who will be involved in program operations so that they can learn how to perform specific functions such as screening, docket management, and cross-system liaison and coordination. Such training programs need not be lengthy but should be thorough. Often, a solid program overview, including a question-and-answer period, can be provided in less than 2 hours.

It is helpful to have a resource book, a loose-leaf compilation of materials about the program. Its contents could include

- A written description of the program, including a discussion of how it differs from traditional practices, the different "phases," and the potential benefits to participants and the community
- A statement of the program goals
- Copies of relevant legislation, regulations, or guidelines
- The program eligibility criteria
- A summary of program requirements (a list of the conditions a participant is expected to meet).

Also helpful for education and training is an operations manual describing the procedures to be used for screening, dissemination of information, informing the defendant about his or her options and legal rights, conducting assessments, supervising defendants' progress in treatment, imposing sanctions or rewards when appropriate, terminating defendants from the program when necessary, and acknowledging completion of the program by successful participants.

Finally, a participant handbook should be provided that answers questions the defendant may have about the program and contains

- A summary of the program evaluation plan
- A list of members of the project planning committee
- A list of the names, addresses and telephone and fax numbers of organizations and individuals that are involved in program operations or program oversight
- Copies of press reports about the program and about similar programs operating in other jurisdictions.

Some of the materials should be widely distributed to judges, lawyers, court staff members, treatment providers, and others involved in program operations. This can be done in the context of a special Implementation Workshops held prior to full-scale implementation.

Education and training for implementation should be treated as important ongoing processes, not one-time events, for at least two reasons. First, staff turnover in many courts, criminal justice agencies, and substance abuse treatment agencies is high. In most jurisdictions, it will be only a short time before some positions crucial for program operations are filled by individuals who did not participate in pre-implementation education and training. The newcomers will need to know why the program has been adopted, and how the program works.

Second, it is likely that changes will be made in program scope and operations in light of experience gained in the implementation process and on the basis of information acquired through monitoring and evaluation. Everyone involved in or affected by the operation of the program needs to know about such changes, the reasons for them, and how they affect individual work responsibilities.

## Startup Operations

Making the program work as intended often begins with a pilot program, during which operational problems can be identified and resolved before full-scale implementation is under way. Among the problems that jurisdictions with functioning drug courts have identified during the startup period are

- Inadequate funding
- Inadequate range of substance abuse treatment services
- Delays in identification or referral of potential program participants
- Need for support and assistance with specific client problems (such as housing, nutrition, medical, and legal services).

This introductory period gives program leaders and managers an opportunity to become familiar with each other's working styles and with a range of clients and their problems. It also enables managers to

- Develop operational procedures
- Locate and eliminate case processing bottlenecks
- Iron out communications problems
- Identify unanticipated management information needs
- Locate and arrange for needed services not initially planned for
- Refine plans for program evaluation.

Because defendants are accepted into a program gradually, there will be a period of time at the outset when the program is operating at less than full capacity. It is only after the program has been in operation for several months (or even as long as a year) and a "full" caseload has been developed that the dimensions of the docket management problems in the court will become apparent. Ultimately, the judge or judges handling this caseload will be performing two key functions: (1) deciding on program admissions for newly arrested defendants who are eligible to participate; and (2) monitoring the treatment progress and compliance with program conditions of defendants already admitted to the program.

As time passes and the number of active participants increases, supervision of the caseload will be increasingly time-consuming. The startup period provides an opportunity to develop approaches to supervision of defendants in a range of cases and can be used to develop management strategies that will work effectively as the caseload increases.

For many of the key players, this will be a time in which they will encounter new concepts and new terminology, will begin developing working relationships, will start working with new procedures and forms, and will find themselves in unfamiliar professional roles. Almost inevitably, there will be some problems, confusion, and miscommunication during this period, and it will take time to develop smooth and efficient operations. Strong and committed leadership is especially important during this period, and program leaders may need to remind stakeholders (as well as members of the program team) that such problems are to be expected during the startup of any complex multi-organization collaborative effort.

## Checking Up on the Program

As the program begins to move from the startup period to full implementation, it will be important to review the initial plans and program design. It is likely that new information acquired during the startup period will point to the need for some changes in program design. If so, key stakeholders and policymakers (as well as members of the program team) should be informed about what has been learned and should be involved in decisions regarding plans for full implementation.

Optimally, this sort of review will be done periodically after full implementation is under way. It is essentially a revisiting of initial policy decisions on the key areas of ongoing operations, case management, and program management based on new information acquired through close monitoring. The following is a checklist of topical areas to be reviewed, with some illustrative questions.

## Ongoing Operations

### Program Goals

- Are the original program goals still sound in light of initial experience with operations?
- If not, how should the goals be modified?
- Are program managers regularly receiving management information that enables them to assess program performance in relation to goals?
- Is the program evaluator confident that information will be available to assess program performance in relation to goals?

### Target Group

- How accurate were the original projections concerning the size and composition of the population of defendants targeted for participation?
- Are targeted participants being screened?
- Are they opting to participate in the program?
- Are the anticipated caseload levels being reached? Exceeded?
- If there is either an over- or under-enrollment of the target population? What adjustments should be made?

### Screening

- How well is the screening process working?
- Is screening being done in all three key areas, substance abuse problems, health and mental health issues, and criminal justice history and current charge? If not, what are the obstacles? How can the obstacles be overcome?
- Is the screening process resulting in identification of all defendants eligible for participation in the program? How rapidly is this being done?
- If screening is taking more than 24 hours from arrest, what are the obstacles to expeditious screening, and how can these obstacles be overcome?
- Are screeners identifying detoxification needs of candidates?

### Detoxification Services

- What detoxification services are being provided?
- What agency provides these services?
- When are they provided, in relation to
  - Initial arrest?
  - Assessment?
  - Decisions of the defendant and the court concerning admission to the program?
- What methods are used?
- How do these methods vary by the type of drug and the severity of the defendants' substance abuse problems?
- What is the duration of these services, and how does this vary by the nature and severity of the substance abuse problem?
- What is the cost (overall and per defendant) of these services?
- Are there other approaches to detoxification that should be considered? If so, why? What are the programmatic and cost implications of possible alternative approaches?

### Assessment for Substance Abuse Treatment

- Who (what agency or agencies and what individuals) performs assessments of candidates for the program?
- What is covered in the assessments?
- When is the assessment conducted in relation to
  - Initial arrest?
  - Commencement of detoxification services?
  - Decisions by the defendant and the court concerning admission to the program?
- How useful is the information in the assessment for purposes of decisions concerning
  - Admission to the program?
  - Matching of the defendant with a particular provider or set of treatment modalities?
  - Actual treatment?
- If completion of the assessment does not take place immediately following referral for assessment, are there any ways in which a partial assessment can be done rapidly to provide information needed for initial decision-making by the court concerning admission?
- What assessment instruments are used?
- How effective are these instruments in producing information useful for decision-making and case management?

### Program Admission Criteria

- In light of initial operating experience, are the program's admissions criteria still appropriate?
- What modifications, if any, may be appropriate in order to reach more (or fewer) members of the target group?
- Are there specific reasons why eligibility and/or admissions criteria should be either tightened or relaxed?
- Are the screening and assessment processes providing the information needed to make sound and expeditious decisions concerning program admissions? If not, what changes need to be made in operating procedures?
- What range of graduated sanctions will be available?

## Case Management Checklist

### Treatment Services

- What substance abuse treatment services are being provided and by whom?
- If there is a single treatment provider, what is the range of services?
- If there are multiple providers, in what ways are their programs different? What gaps exist in the types of treatment services currently available for defendants in the target group?
- How can the gaps be filled?
- What appear to be the initial results of treatment, as indicated by key performance measures (such as urine screens, attendance at counseling sessions, rearrest data, and program reports on participant progress)?
- To what extent, and in what ways, do different approaches to treatment appear to be producing better results?

### Linkages With Ancillary Services

- What ancillary services are directly linked with the program and available to participating defendants?
- What gaps, if any, need to be filled in order to adequately complement the direct substance abuse treatment services? Consider especially
  - Education, including basic literacy and math skills
  - Nutrition
  - Housing
  - Child care
  - Medical treatment
  - Job training and counseling.

### Policies and Practices Concerning Relapse

- How are the judge and other members of the "courtroom team" informed of defendant's progress (or lack of progress) in treatment?
- What actions are taken by the court if reports indicate continued substance abuse and lack of progress in treatment?
- Have clear policies been developed to impose graduated sanctions (consequences) for noncompliance?
- What sanctions are used? Under what circumstances?
- How well do these sanctions work?
- Are there other sanctions that should be considered for use in some circumstances?
- What incentives are available when reports indicate progress in treatment?

### Policies Concerning Termination of Program Participation

- Under what circumstances will a defendant's participation in the program be terminated? How are decisions concerning termination made? What are the roles of the judge, other justice system practitioners, and the treatment provider?
- What is the practical effect of termination on the status of pending criminal charges?
- How many defendants have been terminated from participation in the program before completion and for what reasons?
- Are current policies concerning termination sound? If not, what changes should be made?

### Program Duration, Completion, and Graduation

- What is the duration of the program?
- To what extent and under what circumstances may the time required for completion of the program vary by defendant?
- Are there minimum time requirements or criteria for program completion?
- When and how are these requirements communicated to the defendants?
- What are the practical consequences of successful completion of the treatment program, in terms of the underlying criminal charges?
  - Are charges dismissed?
  - If there has been a guilty plea, can the plea be vacated?
  - Are records sealed?
- What "graduation" ceremonies or other acknowledgments of successful completion of the program take place? What is done on these occasions?
- Are there any changes that should be made with respect to program completion and graduation?

### Aftercare

- What aftercare services are provided for defendants who satisfactorily complete the treatment program?
- Who is responsible for provision of these services?
- How are aftercare services linked to pre-graduation treatment services?
- How are aftercare services paid for?
- What roles (if any) do the court and other criminal justice personnel have in the provision of aftercare services?
- How difficult is it for the defendant to obtain access to these services?
- Are they provided on a proactive "outreach" basis, or must the defendant seek them out?
- What are the criteria for continued provision of (or termination from) aftercare services to specific clients?

### Program Organization and Management Checklist

- How is the program organized for actual operations? Who is responsible for what?
- How (if at all) does the actual operational organization differ from what was contemplated during the planning and program design stages?
- How well is the cross-system collaboration working in practice?
  - What are the strengths?
  - What are the weaknesses?
  - Are there frictions or personality conflicts that need to be addressed?
- What changes in organizational structure are desirable (or necessary) in order for the program to achieve its goals?
- What staffing or consultant needs can be identified? Are there places in which the program is overstaffed or where existing staff are not doing the job well?
- Are there ways in which program scope and staffing should be expanded? Contracted?
- What is the role of the original stakeholder/policy-maker group?
- What is the relationship between the operating program (and its leaders) and the broad stakeholder group?
- How does the stakeholder group regard program operations to date?
- What needs to be done to ensure an effective ongoing relationship between program personnel and the stakeholder group?

### Management Information

- Is accurate information needed for decision-making in individual cases available, on a timely basis, to
  - Judges and court staff?
  - Prosecutors?
  - Defense attorneys?
  - Case managers?
  - Treatment providers?
- What essential information is not readily available?
- What must be done in order to ensure that the information is available?
- Are management information reports necessary for assessment of overall program performance regularly produced?
- Are they disseminated to all of the relevant program team members?
- Do the reports provide information that is accurate and useful for assessing the program's performance in relation to its goals?
- Are they useful for identifying potential problem areas?
- What is not covered by these reports that might be of interest to
  - Program leaders and managers?
  - An evaluator?
  - Key stakeholders including present or potential funding sources?

### Evaluation

- Has an evaluator been selected?
- Is the evaluator fully familiar with the background of the program and with its goals, organizational structure, and operational procedures?
- Has the evaluation design been reviewed by program managers and other key players?
- Does the design address the questions that the program managers and key stakeholders would like to have answered about program operations and impact?
- Is the information needed for evaluation readily available?
- Has the evaluator made any assessment of program operations and impact during the startup period?
- If so, what are the findings?
- Are they consistent with the information available to program managers?
- What are the implications of these findings for full-scale implementation?

### Legal Issues

- Have the pertinent legal issues (seeChapter 8) been addressed in program design and in actual operations?
- Are defendants' constitutional and other legal rights adequately protected under the program's operating procedures?
- Have arrangements been made to ensure the necessary exchange of information between the justice agencies and the treatment providers while still complying with laws regarding privacy and confidentiality?
- Does the program have the insurance coverage necessary to protect against possible liability?

### Costs and Budget

- Have all of the costs of program operation been identified?
- Is there a budget for program implementation that identifies both the costs and the funding sources for all components of program operations for the current and next fiscal year?
- If there are funding gaps, what are the options for filling the gaps or making other adjustments?
- To the extent that the program is supported by grant funding, what plans exist for obtaining more permanent funding at the expiration of the grant period?

### Program and Budget Review

- What mechanisms and procedures have been established for oversight and review of program operations by the original group of stakeholders or a successor group?
- Who should be involved in such a group?
- What should be the role and functions of the oversight or review group?
- How should it relate to the program team?
- What information should it receive?
- How can the oversight or review group best support and reinforce the program team?

### Operations Manual

- Does the program have an operations manual describing its current organizational structure, staffing, and operational procedures?
- If not, what should it include?
- Who should be responsible for preparing the manual and keeping it updated?

(Note that many of the topics covered in these checklists are appropriate for inclusion in such a manual.)

### Information for Participants and the Public

- Does the program have a participants' handbook describing how the program works, rules or conditions governing participation in the program, services provided, treatment procedures and phases, and other aspects of the program?
- If so, does the manual cover everything potential program participants should know and understand?
- Is it written in a language that program participants will be able to read and understand?
- Are there videos or other materials that can help explain program goals and policies to participants and others who may be interested in program operations?
- Have press kits or other such informational packets been prepared to distribute to media representatives, funding officials, or visitors from other jurisdictions who might be interested in how the program works?
- If these materials have not been prepared, who will be responsible for preparing them and keeping them updated?

## Feedback Mechanisms and Program Adjustments

The checklists in the previous three sections can provide a useful tool for periodically reviewing program operations. Given the environment in which these programs exist, one in which laws and policies regarding substance abuse treatment and health care are rapidly changing and in which financial support for public institutions and programs is always under scrutiny, it is critical for program leaders and managers to seek and use information about program effectiveness. Evaluations are one source of such information, but evaluation reports are not always produced in time to help guide programs through mid-course adjustments and funding crises. Effective leaders and managers will constantly be asking practitioners, program participants, and policymakers for information and ideas about program performance, as well as reviewing management information reports to assess progress and identify problems. They develop both formal and informal feedback mechanisms and use the information, in consultation with staff, knowledgeable consultants, and policy oversight groups, to reshape program operations when necessary and to plan for the future.