# Chapter 4—Designing the Program

The general policies and plans developed during the initial planning stage must eventually be shaped into a design for a fully operational drug court. This chapter focuses on nine key issues that must be addressed during the design stage:

- Screening
- Assessment
- Determining categories of care and components of treatment
- Detoxification practices
- Program admission criteria and procedures
- "Relapse" policies and judicial supervision of the defendant's progress in treatment
- Staffing and cross-system liaison
- Management of information
- Program monitoring.

## Screening

Screening is a process used to determine whether an individual is a likely candidate for participation in a treatment program or needs other types of attention. Typically, a program that links substance abuse treatment with pretrial case processing will be limited to defendants who meet certain criteria with respect to the nature of their substance abuse problems, the current charges pending, and their criminal records.

Screening has three purposes:

- To identify individuals who have substance abuse problems that may warrant treatment
- To identify individuals who have infectious diseases
- To identify individuals who fit within the target population of the program in terms of criminal justice criteria.

It is important to recognize that substance abuse and infectious disease screening is not the same as a comprehensive assessment. Screening is done quickly, using relatively simple instruments and methods. A screening instrument does not provide enough information for a clinical diagnosis; rather, it indicates the probability that a particular condition, say, chronic alcohol abuse or TB or a STD, is present. The goal of screening is to quickly identify potential candidates for treatment intervention.

It is important to recognize that screening is not the same as a comprehensive assessment.

Criminal justice screening serves different purposes. Its principal function is to determine the defendant's eligibility for pretrial release or diversion programs linked to substance abuse treatment. Ideally, screening in all three areas, for substance abuse treatment, for infectious disease, and for criminal justice program eligibility, will take place within 24 hours of the defendant's arrest.

### Screening for Substance Abuse

Substance abuse screening is a preliminary gathering of information to determine if an individual has a problem with substance abuse and, if so, whether a comprehensive clinical assessment is appropriate. Personnel doing the screening do not have to be social services professionals, but effective screening does require training. The screening can be done quickly (no longer than 20 minutes) with standard screening instruments. The substance abuse screening process typically involves eliciting responses to questions in five areas:

- Consumption patterns -- the frequency, duration, and quantity of substance abuse
- Feelings of loss of control related to substance abuse
- Extent of physical consequences of substance abuse
- Experience with physiological problems related to withdrawal from substance abuse
- The individual's recognition of problems related to substance abuse.

In addition to interviews or self-administered screening instruments, screening should also include urinalysis, observation of physical signs (such as obvious inebriation or needle tracks) and a review of the individual's criminal history to see if it includes drug use or possession.

The most common substance abuse screening instruments used in treatment programs in the criminal justice system are

- The CAGE questionnaire
- Short Michigan Alcohol Screening Test
- Substance Abuse Screening Instrument
- Offender Profile Index
- AIDS Initial Assessment Jail Supplement
- SALCE (Substance Abuse Life Circumstances Evaluation).

Most of these instruments are described and included as Appendix C in TIP 7, Screening and Assessment for Alcohol and Other Drug Abuse in the Criminal Justice System (CSAT, 1994a).

There are not as many screening instruments for infectious disease as for substance abuse, but CSAT has developed a prototype infectious disease screening instrument that can be used in conjunction with substance abuse screening.

### Screening for Infectious Diseases

There are not as many screening instruments for infectious diseases as for substance abuse, but the Center for Substance Abuse Treatment (CSAT) has developed a prototype infectious disease screening instrument that can be used in conjunction with substance abuse screening. Designed primarily to help identify individuals who may have infectious diseases that are significant public health problems (especially TB, HIV/AIDS, and STDs), the instrument can be administered in about 15 minutes. The results can be used both to help determine suitability for participation in a court-linked substance abuse treatment program and as a basis for referral to a health care facility for further infectious disease assessment and treatment (regardless of whether the defendant enters the substance abuse treatment programs). The prototype instrument is described in detail in TIP 11, Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases (1994c). However, elements of the prototype instruments can be used for making an assessment about defendants' STD risk. TIP 6, Screening for Infectious Diseases Among Substance Abusers (CSAT, 1993b) can also be useful to planners.

### Screening for Criminal Justice Program Eligibility

Eligibility screening for a treatment program linked to pretrial case processing necessarily involves attention to not only to the current charge but also to the defendant's prior criminal history. Often, the criteria for admission to a program will be restricted to defendants facing only particular types of charges, for example, drug possession or driving under the influence. Admission to a program may also be restricted to individuals with no past convictions for violent offenses and no currently pending charges involving violence. Sometimes programs may exclude individuals currently on probation or parole.

Screening related to criminal justice eligibility ordinarily involves examination of arrest and complaint papers relating to the current charge and review of criminal history data available through local, State, and sometimes national criminal records repositories. It may also involve an interview with the defendant and contacts with the defendant's family or others in the community to determine whether or not the defendant has a place to live if released from custody.

### Personnel Responsible for Screening

Screening personnel do not need to be highly trained social service professionals. It is important, however, that substance abuse treatment professionals or criminal justice program staff responsible for screening functions be well trained in the use of screening instruments and other methods of identifying substance abuse problems and risk factors for infectious diseases.

Criminal justice personnel can be trained to do some or all of the initial screening. Optimally, the screening will be done before the defendant's initial court appearance. Personnel from any of the following agencies (or a combination of them) can do the screening:

- The law enforcement agency that makes the initial arrest and does the booking
- The sheriff's department or other agency in charge of the jail
- A pretrial services agency
- A TASC (Treatment Alternatives to Street Crime) agency that works with the court
- A newly created drug court program agency.

Criminal justice personnel can be trained to do some or all of the initial screening.

Interviews with a defendant about substance abuse and infectious diseases should be accompanied by a clear explanation of the purposes of the interview, the defendant's rights regarding confidentiality, and any limits on the confidentiality of information obtained through the interview. The screening interviews should be conducted in private, preferably by non-uniformed persons trained in cultural competency as well as in substance abuse and infectious disease screening methods. Screeners should be supervised by program managers to ensure consistency and quality, and to make sure that they are aware of the program's current eligibility and suitability criteria.

## Assessment

### Assessment for Substance Abuse Treatment

While screening is focused on program eligibility and on potential substance abuse and infectious disease problems, assessment is a more comprehensive set of procedures, intended to confirm or refute the results of the initial screening, identify the specific substance being abused , any coexisting health problems -- particularly mental health disorders -- and begin formulating a treatment plan. For more information on coexisting mental illness and substance abuse disorders, see TIP 9, Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse (CSAT, 1994b). One assessment instrument used by substance abuse treatment professionals is the Addiction Severity Index (ASI), which must be administered by a clinician and takes an hour. The assessor develops and analyzes information about the nature and extent of the defendant's substance abuse history, mental and physical health problems, social and economic status, and readiness for treatment. The types of treatment and ancillary services required to address the problems are then identified.

### Components of an Assessment

A comprehensive assessment for substance abuse treatment is a thorough evaluation of the individual, using multiple procedures and sources of information, to establish the presence or absence of a diagnosable disorder or disease and lay the clinical foundation for treatment.

Ordinarily, a clinical assessment addresses issues in three broad domains of an individual's life: social, psychological, and medical. Each of these domains includes a number of specific components.

Elements to assess in the social domain include

- History of substance abuse, including drugs used, frequency and pattern of use, previous treatment, and drug-using patterns in the family
- Involvement with the criminal justice system, including prior criminal history and any pending charges
- Family history and social roles, including the individual's roles in the immediate and extended family, as well as employment status
- Educational and vocational needs
- Employment and salary history (socioeconomic status)
- Spirituality, including the offender's sense of community and "sense of belonging in the universe"
- Experiences with domestic violence and child abuse/neglect.

Components of the psychological domain include

- Level of psychological development
- Levels of anxiety and depression
- Risk of and/or history of prior treatment for mental illness
- Use of any medication for mental health purposes
- Presence of personality disorders or other mental disorders
- Central nervous system function and impairment
- History of sexual, emotional, and/or physical abuse
- History of violent behavior.

Areas to assess in the medical domain include

- Risk of and/or history of infectious and contagious diseases, including HIV, hepatitis, STDs, and TB
- Medical problems, including nutritional deprivation, and dental problems. A medical examination should be conducted to determine health status. Tests for the presence of infectious diseases also should be conducted.

Program personnel must follow State and local laws and regulations when developing assessment questions concerning health issues. In some States, for example, asking questions about HIV/AIDS status is illegal or subject to laws and regulations concerning confidentiality. On the other hand, some states, such as Arizona, require that injection drug users be tested for HIV.

The information gathered usually is written up as a summary statement that integrates the information acquired, the diagnostic impressions of the assessor, and the recommendations for treatment.

### Personnel Responsible for Assessment

Unlike screening, assessment requires substantial experience in clinical settings. Ordinarily, the person doing the assessment should have a master's degree and clinical experience. Psychologists, social workers, certified addictions counselors, and clinical nurses are among those qualified to administer the psychological and sociobehavioral parts of the assessment. The biomedical portion of the assessment is usually best performed by a health professional with training in diagnostic skills, such as a physician, nurse, or physician's assistant.

The justice system in the jurisdiction may already have personnel who can conduct portions or perhaps all of a clinical assessment. For example, some pretrial service agencies, TASC programs, probation departments, and local jails have social services and health professionals on staff who are qualified for this work. In addition to an appropriate educational and clinical background, staff responsible for the assessment should be culturally competent and should have skills in establishing rapport with the defendant; maintaining a nonjudgmental, nonthreatening attitude; and succinctly documenting information.

### Timing of an Assessment

An assessment should follow arrest as quickly as possible -- a primary treatment objective is to take advantage of this crisis in a substance abuser's life. Further, judges and prosecutors are concerned about the expeditious processing of cases. If a defendant is to be considered for deferral of prosecution and placement in treatment, information about his or her treatment needs must be readily available.

One of the primary objectives of these programs is to take advantage of the crisis in a person's life typically caused by an arrest.

As a rough standard, many jurisdictions that have developed drug courts in recent years attempt to place eligible defendants in treatment 1 to 2 days following arrest. However, in order to provide effective treatment services, a longer period may be needed for a complete assessment. The scope and timing of the assessment are critical issues in the design of a drug court program, and should be a subject of discussion and negotiation among the treatment providers and justice system leaders. It may be possible to develop a two-stage assessment process, an initial step that provides information needed by the court for its basic decision about referral to treatment (more than initial screening; less than full-scale assessment), and a second stage that provides more complete information, enough for the treatment provider to make a specific referral and for the court to monitor the defendant's performance in treatment.

### Assessment Instruments

The treatment field uses numerous questionnaires and instruments to collect information from the substance user. Two of the best known are the

- Addiction Severity Index (ASI), which requires about 60 minutes to administer and is available from the National Institute on Drug Abuse.
- Wisconsin Uniform Substance Abuse Screening Battery, which requires a fee for use, but which provides comprehensive data.

The Fifth edition of the ASI is reprinted in TIP 7, Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System (CSAT, 1994a), which also includes instruments for assessing AIDS risk and for determining the appropriate type of substance abuse treatment. That TIP also describes a number of other instruments used for assessment.

All assessment questionnaires have strengths and weaknesses, and treatment professionals' preferences are based on particulars from clients' situations to communities' needs. Many programs cobble together parts of various instruments.

One way to select an assessment instrument or group of instruments is to form a focus group of local treatment professionals who understand the target population and the cultures of individuals who routinely come before the court to select the treatment instrument(s). Culture-specific instruments should be reviewed by people knowledgeable about the culture to ensure that the questionnaires ask the target group the right questions and are not skewed to misinterpret behaviors of minority cultures as aberrant. Instruments should be translated into the language of the population(s) being assessed.

### How Are the Results of an Assessment Used?

At each stage in the processing of criminal defendants, those doing the screening and assessments must balance the risk to public safety against the treatment needs of the client. This risk/needs assessment should be incorporated into a mutually reinforcing supervision and treatment plan. That plan should include incentives and graduated sanctions as part of supervision as well as treatment interventions and social services that constitute a continuum of care.

The assessment should lead to a diagnosis of the extent and severity of addiction and the problems it has created in the individual's life. It should also lead to a treatment plan, agreed to by the treatment provider and the individual and approved by the court, that states specific goals for recovery and outlines steps to begin and maintain the recovery process.

Judges and other justice system officials will need to know all recommendations made regarding the proposed plan of treatment based on the results of the assessment. If the assessment is conducted in two stages, as discussed above, the justice system officials must review the results of both. The results of the first, more cursory stage will help a court decide whether to place the defendant in a treatment program. The second part will guide the choice of conditions the defendant must meet. Judges, prosecutors, and the defendant's own lawyer need to know what goals and objectives have been set for the treatment plan, how they are to be measured, and when and how they will receive information about the defendant's performance in treatment.

## Determining Categories of Care and Components of Treatment

In designing a drug court program, planners must make difficult decisions about the types of services that will be available through the treatment program, and about where, when, by whom, and for how long these services will be provided for the target population. Because substance-abusing populations and treatment resources that are available (or that can, realistically, be developed) vary widely from jurisdiction to jurisdiction, each is likely to develop its own approach. This section provides general information on categories of care and treatment modalities that are widely (although not universally) available. It is up to the program planners in each jurisdiction to decide what categories of care and treatment modalities and services make sense for the target population.

### Categories of Care

Substance abuse treatment services range across a continuum that comprises three major categories of care: pretreatment services (education/prevention); outpatient treatment; and inpatient treatment (including residential treatment).

#### Pretreatment Services

Pretreatment services include primary prevention (for those who have not yet abused alcohol and other drugs) and early intervention (for people who have begun to abuse alcohol and other drugs and are considered to be at high risk for developing problems related to use). Pretreatment services are not part of primary treatment. They typically consist of psychoeducational services designed to increase individuals' awareness of the dangers of substance abuse.

#### Outpatient Treatment

This is the most common form of substance abuse treatment, including both 1/2- to 1-hour individual sessions and intensive day treatment centers. Outpatient treatment has advantages over inpatient or residential treatment (for clients who are not in need of acute care) in that the client can maintain or seek employment, remain with family, and maintain contact in the community during the treatment process. Types of outpatient treatment include

- Non-intensive outpatient treatment
- Intensive outpatient treatment
- Opioid substitution therapy
- Day treatment, partial hospitalization, or day reporting centers.

#### Inpatient Treatment

This type of care can be provided in a hospital or medical facility (for those with the most acute treatment needs), or in a wide range of other types of therapeutic residential settings, such as apartments, dormitories, and supported housing. The residential programs may be secure or non-secure facilities, and the length of stay and costs of treatment can vary considerably. Types of inpatient treatment programs include the following:

- Medically managed intensive inpatient treatment (hospital-based)
- Short-term non-hospital intensive residential treatment (hospital-based)
- Intensive residential treatment
- Psychosocial residential care
- Therapeutic community
- Halfway house
- Group home living.

Length of treatment is an issue closely related to the category of care. To a significant extent, the length of treatment offered by many providers has been shaped by insurance companies' policies concerning payment for treatment services. For example, insurance companies have commonly used a standard of 28 days for reimbursable residential treatment, and many private treatment providers have designed 28-day residential programs. The needs of the pretrial defendant target population, however, will seldom fit the 28-day model. Recent research has verified that clients in a criminal lifestyle that includes substance abuse need a minimum 90-day treatment intervention to change their behavior. Most treatment drug courts provide for at least six months of supervision and treatment services. Justice system officials and substance treatment providers together should develop cost-effective programs that can meet the needs (and limitations) of the target population, the justice system, and the treatment community.

#### Detoxification Practices

Detoxification is the process through which a person who is physically dependent on alcohol, illegal drugs, prescription medications, or a combination of these drugs undergoes medically supervised withdrawal from the drug or drugs of dependence. Detoxification is an important part of the treatment process, because it is difficult to properly assess an individual or provide treatment for the underlying substance abuse if the individual is inebriated or in the early stages of withdrawal. In severe cases of dependency or withdrawal, the individual may be unresponsive to questions. Detoxification stabilizes chemically dependent defendants and allows them to move on to the next step in their recovery.

Dade County has used existing hospitals while building its own detoxification services for outpatient use.

Withdrawal symptoms can range from mild discomfort to acute, even life-threatening symptoms such as convulsions, hallucinations, suicidal ideation, and severe depression. Medication can reduce some of the discomforts of withdrawal and minimize medical complications. Blood pressure monitoring and medical supervision may be required, depending on the drugs used by the defendant and the clinical symptoms of withdrawal. TIP 19, Detoxification from Alcohol and Other Drugs (CSAT, 1995), provides guidelines for safe, medically managed withdrawal.

Some jurisdictions, such as Dade County, Florida, have used existing services such as hospitals while building their own detoxification services for outpatient use. In addition, jail detoxification and treatment programs have been used to treat more difficult cases. Once the unique needs of substance-abusing offenders are identified, many programs have tailored their detoxification procedures to fit client needs.

Many communities have detoxification centers, either in a criminal justice or social services environment, that are supervised by a nurse and have a physician on call. Some hospitals, both public and private, have detoxification units that range in duration and intensity from short-term to long-term programs.

From a program design standpoint, there are several key questions that must be addressed with respect to detoxification:

- What agency or agencies will provide detoxification services for arrested defendants? Are different approaches and facilities needed depending on (a) security/custody needs with respect to the defendant; and/or (b) the level of substance abuse and probable severity of the withdrawal?
- How can screening procedures be used to help identify the detoxification needs of defendants?
- How and when will defendants needing detoxification services be transported to the appropriate detoxification facility?
- What specific detoxification services will be provided? By whom? For what period of time and at what cost?

In addition to traditional withdrawal methods, acupuncture, an approach taken from Eastern medicine, is now being used as an adjunct to assist in the detoxification process in some jurisdictions. Several research studies have indicated that acupuncture can be effective in reducing cravings and in ameliorating withdrawal symptoms. The first court-linked program to extensively use acupuncture was in Miami, Florida. Acupuncture is now an integral part of court programs in a number of U.S. jurisdictions.

Before introducing acupuncture as part of a drug court program, it is important to coordinate efforts with public health officials to ensure that certification requirements can be met. In California, acupuncturists are required to obtain the equivalent of a 4-year medical degree. Acupuncture is offered as an adjunct to treatment in many substance abuse treatment programs. Although full-body acupuncture requires a facility that has beds and changing rooms, it is possible to use much simpler (and less expensive) clinic style methods. Current use of acupuncture to help with detoxification generally involves a five-point auricular (ear) application. This procedure can be applied by trained technicians to clients who are sitting in chairs. This procedure is less expensive than full-body acupuncture, and a State's medical authority may certify it for use in treatment programs.

It should be noted that some substance abuse treatment professionals object to acupuncture because they see it as a hindrance to treatment. Some believe that acupuncture replaces the "needle ritual" that is part of some drug users' lives. Others say that the calming effect of acupuncture can undermine other treatment, which sometimes requires confrontational approaches.

In designing a court-linked substance abuse treatment program, planners should consider what role , if any, acupuncture should play and what safeguards are needed to ensure that acupuncture procedures are appropriately and safely used.

Planners may also want to consider detoxification approaches that are culture-specific. For example, Native Americans use sweat lodges for a variety of ritualistic and social purposes. Assignment to a sweat lodge may be appropriate action to take for Native Americans who do not exhibit life-threatening symptoms, provided they meet other criteria of program eligibility. Latinos and Hispanics may also use herbalists and "curanderos" who treat withdrawal symptoms with traditional remedies. Although the efficacy of such culturally based methods of detoxification is not yet fully documented by researchers, the psychological and social benefits to the individual who believes in these traditions may be considerable.

### The Components of Treatment

Most treatment providers offer a range of treatment services. It is important to remember that not all programs will provide all services and that the level and focus of services provided may vary widely from program to program. However, services generally include

- Evaluation and assessments: medical, psychiatric, and substance use assessments
- Treatment planning: medical, psychiatric, and addiction treatment planning
- Counseling/therapy: group therapy, individual counseling, family therapy
- Medical assessment and treatment, including attention to HIV/AIDS, hepatitis, TB, and STDs
- HIV/AIDS education, testing, and counseling
- Comprehensive pregnancy care: prenatal care, parenting classes, childbirth classes
- Mental health services, including medications when indicated
- Education about substance abuse: lectures, interactive groups, videos, reading assignments, journal and writing assignments
- Self-help education and support, including Alcoholics Anonymous (AA) and Narcotics Anonymous (NA)
- Social and other support services for the offender and family members
- Relapse prevention services
- Substance abuse treatment services to family members and significant others
- Acupuncture and other nontraditional detoxification and healing techniques
- Services for special populations, such as violent offenders, incest survivors, incest perpetrators, and those with dual disorders.

In addition, the treatment provider usually tries to link the client with a variety of ancillary services to address other problems. These may include

- Education, including basic reading and math skills
- Job training and counseling
- Housing
- Child care
- Nutrition assistance.

Treatment providers increasingly note that many clients require "habilitation," not simply "rehabilitation." In other words, some addicted persons have not lost functional capacities and skills as a result of their addiction but have, in fact, never acquired them. Many persons, for example, have not acquired the capacity to control impulses or to distinguish between emotional states. Some lack the skills to sustain day-to-day relationships with others, or suffer from Attention Deficit Disorder. The fact that more and more clients suffer from a lack of basic capabilities and skills makes the treatment of the underlying addiction more difficult.

Treatment providers increasingly note that many clients require "habilitation," not simply "rehabilitation."

#### Aftercare

Components of aftercare in treatment programs typically include

- Random drug testing
- Self-help groups (AA, NA)
- Acupuncture (in some jurisdictions)
- Group counseling
- Individual counseling
- Employment
- Education
- Mentoring
- Strengthening family and community ties.

Aftercare is a critical component of treatment. Even when an individual has completed a treatment program satisfactorily, the danger of relapse remains. This is especially true when the client returns to the community after time in a residential program and is confronted by the conditions (including friends), that promoted substance abuse before treatment. In designing a drug court program, it is important to devise aftercare services in which the client has routine access to self-help groups and counseling sessions.

#### Culturally Specific Treatment Programs

The last decade has seen much greater attention paid to the role of each client's culture in the treatment process. Because treatment is so intense and stressful, it is preferable for clients to obtain services not only in their native language but sensitive to their culture's patterns of beliefs, feelings, and behaviors. For example, Western cultures tend to stress individualism and self-control, and clients from more family-centered cultures respond better to a family-oriented approach to treatment. In traditional Western cultures, introspective discussion of one's personality and behavior in a group setting is not uncommon, but such self-disclosure is utterly foreign in some other cultures. The best treatment programs take their clients' cultural backgrounds into account.

Both substance abuse treatment and criminal justice professionals often fail to appreciate the great diversity among the immigrant groups in the United States. For example, Spanish-speaking cultures are treated as one "Hispanic" entity, even though Mexican, Puerto Rican, Cuban, and Central American cultures differ significantly from one another. It is very important for criminal justice-based treatment programs to be sensitive to these and other areas of diversity, and to make certain that treatment resources include programs for the principal ethnic and racial minorities in their jurisdictions.

## Program Admission Criteria and Procedures

There is a discussion in Chapter 3 of issues regarding the target population and possible points of intervention. During the program design stage, initial plans concerning these issues must be translated into decisions about the types of defendants who will be eligible for the program, what information and advice these defendants will be given concerning possible participation in the program, and when and how participants will be selected.

The issues of eligibility and suitability relate directly to the screening function discussed at the start of this chapter, and, more broadly, to the overall goals of the program. In the design stage, the program goals, together with the planners' knowledge about treatment resources that are available or can be developed, should help shape the criteria for admission to the program.

In general, jurisdictions that have initiated treatment programs for pretrial defendants begin by targeting those regarded as relatively low-risk offenders in terms of public safety considerations. For example, defendants with a history of committing violent offenses are often not eligible for a treatment program even if their current charge is a nonviolent one (such as possession of an illicit drug). In some places, as programs have gained experience and developed credibility with the public and with justice system officials, the eligibility criteria have been expanded to include a broader range of defendants.

Examples of eligibility criteria used by drug court programs include

- Current charge of purchase or possession of a small quantity of illegal drugs; may also include possession with intent to sell or distribute
- Current charge of another nonviolent offense (for example; theft, forgery, passing worthless checks, prostitution, or burglary), committed while under the influence of drugs or alcohol
- Current charge of operating a motor vehicle while intoxicated or under the influence of drugs or alcohol
- History of substance abuse problems, including recent abuse
- Criminal history that does not include conviction of a felony crime or violence
- Willingness to participate in a treatment program, having been informed of the conditions of participation.

In the design stage, the program goals, together with the planners' knowledge about treatment resources that are available or can be developed, should help shape the criteria for admission to the program.

Suitability criteria are more difficult to apply. It is clear that there are some situations in which, although technically meeting the eligibility criteria, the defendant is unlikely to benefit from the program, may disrupt program activities, or may need medical attention before being considered for admission to the program. Examples of categories of defendants often not accepted into a program include drug traffickers and dealers; defendants who have severe psychological problems (e.g., persons who may be receiving psychiatric medication but are not stabilized on their medication); and defendants with medical conditions that require immediate attention.

Establishing clear criteria for admission to the program is a critical first step. With these criteria in place, the design team can develop additional procedures for identifying defendants who are both eligible and suitable for admission to the program. Because jurisdictions organize post-arrest case processing in different ways and have differing legal requirements concerning issues such as speedy trial rights, appointment or assignment of counsel, and use of deferred prosecution or deferred judgment, there is no single sequence of events that is appropriate for every jurisdiction. However, the design team in any jurisdiction should be prepared to address the following questions:

- Who (what agency or agencies and what individuals) will conduct the initial screening for criminal justice charges and prior history, substance abuse, and infectious disease problems? Where will this be done? What access will the screeners have to criminal history information?
- Who will be responsible for informing the defendant about the possibility of participating in a treatment program? When will this be done? What information will be provided to the defendant at this time?
- At what stage will the defendant have the opportunity to consult with defense counsel concerning the possibility of participating in the treatment program? What information will the defendant and defense counsel have at that point, concerning the current charges against the defendant and the duration and conditions of participation in the program?
- What are the potential benefits to the defendant from "successful" participation in the program (e.g., dismissal of charges; vacating of plea or conviction)?
- What rights, if any, will the defendant have to waive or relinquish in order to participate in the program? Will a plea of guilty, or agreement to stipulated facts, be required as a condition of participation?
- How much time will the defendant have to consider the possibility of participating in the program? Regardless of the defendant's initial decision, will there be an opportunity for reconsideration?
- How will the court, the prosecutor, the defense counsel and the defendant know if there is an open "slot" in a treatment program appropriate for the defendant?
- What role does the treatment provider have in the initial decision to admit the defendant to the program? How will this vary if the program uses multiple providers?
- What role does the prosecutor have in the initial decision concerning admission of the defendant to the program?
- How soon after the initial arrest does the judge consider the defendant's admission to the program? What information and recommendations will the judge have at that point? From what sources?
- What is the range of options available to the judge concerning admission of the defendant to the treatment program and establishment of conditions for participating in the program? What conditions will usually be imposed and what factors control their imposition? To what extent, and how, will urine testing be used as a condition of program participation?
- When will treatment begin once a defendant is admitted to the treatment program?

Every jurisdiction that has established treatment programs linked to pretrial case processing has answered these questions in its own way.

## "Relapse" Policies and Judicial Supervision of the Defendant's Progress in Treatment

One of the hallmarks of the newer drug court programs is a strong emphasis on active judicial oversight of the defendant's performance in the treatment program.

### The Judge's Supervisory Role

The judge will generally require the defendant to appear at regularly scheduled status hearings, at which the defendant's treatment progress is reviewed. While patterns vary from court to court, the status hearings may be held as often as once a week during the first month or so. As treatment progresses (and especially if the defendant appears to be making satisfactory progress), the frequency of the status hearings decreases, but the court continues to monitor the defendant's performance.

At the status hearing, the judge reviews reports from the case manager or treatment provider and possibly from other parties that have a role in the treatment process. Topics covered at the hearing ordinarily include

- Substance use test results (e.g., urinalysis)
- Report on defendant's attendance at treatment sessions
- Report on defendant's attitude toward treatment, including recognition of the substance abuse problem.

In addition to these substance abuse and treatment-specific topics, the judge may also inquire about other aspects of the defendant's life, including housing, work, family, and general health. The judge can thereby develop rapport with the defendant and support the defendant's efforts to overcome the substance abuse problems.

### Developing Participant Accountability

One key aspect of judicial supervision of the defendant's performance in treatment is the use of sanctions when a defendant fails to comply with program conditions and rewards for continued abstinence. The ways in which sanctions and rewards are used varies considerably from jurisdiction to jurisdiction, but their use reflects an orientation very different from the traditional response of the court to substance-abusing offenders.

Traditionally, if a defendant was caught using alcohol or drugs in violation of conditions of probation, his or her probation was revoked. By contrast, programs that integrate substance abuse treatment with pretrial case processing deal with renewed use of alcohol or other drugs as part of the recovery process.

Most individuals with severe substance abuse problems have few coping skills to help them deal with situations where they are tempted to use alcohol or drugs. "Relapse" (sometimes called "backsliding") is common. Indeed, many substance abusing individuals relapse and return to treatment several times before achieving abstinence from alcohol or drugs for any appreciable duration. But the fact that relapse is common does not mean that it is ignored. On the contrary, one of the functions of the judge in an integrated program is to take appropriate action to reinforce the treatment program.

A treatment report that presents evidence of relapse (for example, a succession of positive urinalyses for drugs for a drug-using defendant; failure to attend treatment sessions) is a signal to the court that the treatment plan needs to be reviewed and that some type of sanction is probably needed. Sometimes a verbal admonition by the judge is all that is needed. At other times, it may be necessary to increase the frequency of urine testing and counseling sessions, or to schedule more frequent status review hearings. If these approaches don't work, it may be appropriate to place the defendant in jail or a community correction facility, perhaps increasing the duration of imprisonment at each violation.

Jurisdictions vary considerably in the policies they follow in responding to noncompliance with program conditions. The main point is to ensure that there are consequences for noncompliance, and that they are imposed fairly and consistently.

When defendants perform well in treatment, there should be some recognition and reward for their progress. One obvious reward is the dismissal or lessening of charges upon successful completion of the treatment program. It also helps to acknowledge progress along the way -- even modest progress. For example, a succession of negative urinalyses for drugs and regular attendance at treatment sessions can be publicly acknowledged by the court at a status review hearing. Such progress can also be rewarded by reducing the frequency of status hearings or the intensity of the treatment program. Some programs conduct a graduation ceremony and award certificates when defendants successfully complete treatment.

## Staffing and Cross-System Liaison

Staffing for an integrated program requires teamwork across agencies and institutions that generally have little history of working collaboratively. As noted earlier, this new team needs to develop a plan that ensures client accountability through a balance of supervision and graduated sanctions and treatment interventions. Those elements should be seen as mutually reinforcing.

For justice system members of the integrated program team, involvement in the program means shifting their primary focus from the guilt or innocence of the defendant to effective interventions for defendants admitted to the program.

Optimally, members of the program team for the pilot or startup phase of the program will have had some involvement in the initial planning and in the detailed design of the program. Planning and designing the program will give team members a basic core of knowledge about substance abuse treatment and will familiarize them with the approaches and techniques used in other jurisdictions. While the composition of the teams and the precise roles and responsibilities of each team member will vary, it is possible to identify some important court-based roles and functions that will be common to most integrated programs:

### The Judge

The judge will play a central role in the program. Generally, the judge will explain the defendant's legal rights and options and the program requirements at the defendant's first court appearance and right before admission to the program. The judge will also review treatment progress reports and discuss progress directly with the defendant at status hearings.

### The Prosecutor

The prosecutor will generally ensure that program participants meet the established admissions criteria; will review treatment progress reports and ask the judge to impose sanctions if the defendant fails to comply with program requirements; and may seek to remove from the program participants whose treatment reports show no progress or who are arrested again for some kinds of criminal conduct.

### The Defense Attorney

The defense attorney will review the charges against the defendant as well as any information available from police reports or other documents disclosed by the prosecutor; will advise defendants about their constitutional rights (e.g., right to counsel, right to speedy trial) and practical options, including participation in the treatment program; will explain how various treatment program outcomes will affect the disposition of the case; and, if a defendant opts to participate in the program, will encourage and support the defendant's participation and compliance with program conditions.

### The Screening Officer

A screening officer, who may be a pretrial services officer, TASC program coordinator, a member of the jail administrator's staff, or the incumbent of a newly created position, will be expected to review the list of defendants arrested each day, and will screen each case for program eligibility based on criminal justice criteria such as current charges and prior record. This individual may also conduct screening for substance abuse problems and infectious diseases and may supervise defendants released from custody for compliance with program conditions, including periodic urine testing.

### The Court Clerk

The court clerk or court coordinator will help schedule status hearings and other court appearances; organize and prepare files for cases on each day's calendar; help the judge review the status of cases subject to judicial supervision; follow up on defendants who fail to appear in court as scheduled; and stay in regular communication with the judge, the treatment program liaison officer, and others involved in program operations.

### The Assessment Officer

The assessment officer, typically an individual with master's-level training in a discipline associated with substance abuse treatment, or the equivalent in actual experience, will conduct the detailed assessment of substance abuse problems described earlier in this chapter and make recommendations concerning the appropriate category of care and type of substance abuse treatment.

### The Case Manager

Case management is a term used by both the court and treatment/supervision agencies. In the court, a case manager helps the judge manage the court's pending caseload and daily calendars and acts as liaison with representatives of agencies involved in the work of the court (including treatment providers). In the treatment community, the case manager is primarily the coordinator of a team of service providers, including both treatment and ancillary services such as housing, medical care, nutrition, literacy training and job placement. In some jurisdictions, the latter function is performed by the treatment program liaison officer.

### The Treatment Program Liaison Officer

This person will help explain treatment program operations to defendants who may participate in the program; will ensure that treatment progress reports are provided to the judge and to the prosecutor and defense lawyer in advance of status review hearings; will provide information on available treatment slots; and will help arrange for transportation of the defendant to the treatment program.

The titles and responsibilities of individuals participating in the program team, as well as the organizations and agencies with which they are affiliated, will vary from community to community.

This listing of staff roles is to some extent oversimplified. In actual practice there may be some revision or consolidation of roles and perhaps some additional functions. The titles and responsibilities of individuals participating in the program team, as well as the organizations and agencies with which they are affiliated, will vary from community to community.

Moreover, while there are strong arguments for beginning program operations with a relatively small and cohesive interdisciplinary team, it is important to remember that many other persons may become involved in program operations at an early date.

In a large multi-judge court, for example, it is possible that there may be more than one judge (and more than one courtroom team) involved in the integrated program. Further, it is likely that there will be some turnover in the judges and staff assigned to the program team. Optimally, the initial personnel will hold their posts long enough to establish the roles of all of the team members and regular mechanisms for communication and exchange of ideas.

Staffing for an organization that provides substance abuse treatment integrated with pretrial case processing will vary depending on the volume of cases, the categories of care provided, the components of the treatment program, and the ways in which the treatment program is linked to other social services in the community. The director or chief executive officer of any organization that provides treatment services integrated with pretrial case processing should be regarded as a member of the program team. So, too, should the counselors, case managers, and other treatment professionals who will be working with pre-trial professionals. These treatment community professionals need to understand the operation and expectations of the justice system, just as justice system professionals need to understand substance abuse treatment.

## Management of Information

Information, about individual defendants and about treatment programs, is essential for the effective management of both individual cases and the overall drug court program.

On an individual case basis, information about the defendant is needed to make initial screening decisions, to do a detailed assessment of the defendant's treatment needs, and, if the defendant is admitted into the treatment program, to monitor progress in treatment, make revisions in the nature or intensity of treatment provided, and impose sanctions or reward progress when appropriate. This information is needed by the court, the treatment provider, and sometimes by the prosecutor and defense lawyer. Signed waivers and exchange of information are critical elements of the drug court operation. Some information, particularly information about the defendant's performance in treatment, may not be readily accessible unless carefully drafted waivers of confidentiality and interagency agreements governing the exchange of information have been adopted and are used.

This is an area in which modern technology holds great potential for far more rapid and comprehensive exchange of information between treatment system and justice system agencies than would have been possible in earlier years. With automated databases in the courts and in many treatment agencies, and with the availability of electronic communications mechanisms such as e-mail and faxes, the transmission of information relevant to case monitoring and decision-making can be almost instantaneous. Some jurisdictions, such as Denver and Washington, D.C., make very effective use of online linkages between treatment providers and judges who have computers on the bench. When a defendant appears in court for a status hearing, for example, the judge can directly access information about the defendant's recent urine test results, attendance at treatment sessions, and compliance with other conditions of program participation.

With automated databases in the courts and in many treatment agencies, and with the wide availability of e-mail and faxes, the transmission of information relevant to case monitoring and decision-making can be almost instantaneous.

While many jurisdictions do not currently have such online exchanges of information, it is essential for the design team to develop mechanisms that will ensure the rapid and complete exchange of information needed -while observing the laws and regulations governing the confidentiality of information.

The categories of information needed by the justice system and by treatment providers for decision-making about individual cases are remarkably similar. They include

- Identifiers and locators such as name, age, sex, race/ethnicity, address, phone, fingerprint identification number, and court case number
- The current charges against the defendant and the facts allegedly supporting the charges
- The defendant's criminal record, particularly any previous convictions for offenses involving violence
- The defendant's community ties, including family situation, housing, and employment
- The defendant's prior record of appearing for scheduled court dates
- The defendant's past involvement with substance abuse treatment
- The nature and severity of the defendant's substance abuse problems
- The nature and severity of any medical or mental health problems
- If the defendant is admitted to the treatment program, up-to-date information on court case status and performance in treatment, including attendance at treatment sessions and results of tests for use of drugs or alcohol.

Information about individual cases and defendants, in addition to being essential for case-level decision-making, also serves a second vital purpose: providing the building blocks for effective overall program monitoring and evaluation.

## Program Monitoring

Monitoring and evaluation are closely related concepts, but they are not the same thing. Monitoring is an ongoing or periodic observation of program operations. The main purpose is to ensure that the program stays on course and that the operational procedures are revised if necessary. In the case of a drug court program, policymakers and program managers should monitor operations using indicators of program performance. These might include, for example,

- Number of defendants screened for program eligibility and for substance abuse problems and infectious diseases, and the results of those screening activities
- Number of substance abuse treatment assessments conducted and the results of those assessments
- Number of persons admitted to the program
- Number of persons rejected despite screening that indicated eligibility, and the reasons for the rejection
- Characteristics of defendants accepted or not accepted into the program, by
  - Demographics (age, sex, family status, race/ethnicity, employment status, and education)
  - Current charges
  - Criminal justice history
  - History of treatment
  - Medical needs (including detoxification)
  - Nature and severity of substance abuse problems
  - Results of drug tests.
- Caseload status of persons in the treatment program, including
  - Number of cases by length of time in treatment (0-30 days, 30-60 days, etc.)
  - Number of cases by completion of stages of the treatment process.
- Number of persons who complete treatment successfully
- Number of persons terminated from the program, including
  - Reason(s) for termination
  - Length of time in the program.
- Accomplishments of program participants in terms of
  - Sustained abstinence from alcohol and other drugs
  - Improved job skills
  - Improved literacy skills
  - Improved health
  - Improved life skills.

Having knowledge about these factors, and others selected as key indicators of performance, should enable program managers to accurately assess the program's effectiveness, and make good decisions about operational procedures and resource allocation. The data needed for program operations usually can be obtained from information used for day-to-day operations and routinely collected for each individual in the program. Although many programs rely on outside evaluators to provide them with information on these topics, it should not be necessary to do so. With careful attention to the development of databases and computer software report formats (perhaps supplemented by manual counting in some instances), program managers can have such information monthly or weekly. Maintaining and sharing such information and using it to analyze program operations can make a significant difference in the effectiveness of a program.

The data needed for program operations usually can be contained from information used for day-to-day operations and routinely collected for each individual in the program. Evaluation, discussed in more detail in Chapter 6, also involves periodic observation of operations, but the focus is primarily on assessment of a program's effectiveness in achieving its original goals. Evaluation should draw on the same information base that enables policymakers and program managers to monitor operations. Feedback from evaluators, who are typically outside the day-to-day operations of a program, can be helpful in supplementing what the policymakers and managers know from monitoring program operations. However, if the policymakers and managers are doing a good job of monitoring, evaluation reports should seldom contain surprises.

Close attention to information needs, for individual case decision-making in both the justice system and the treatment community, for monitoring, and for evaluation, should be a part of the design stage for every program. It will be a critically important element of program operations.

### Revising the Memorandum of Understanding (MOU)

When the design issues discussed in this chapter have been resolved, everyone involved in development of the program will know much more about key issues and operational details than they did when the policy development phase ended and design work began. It may be necessary to revise the Memorandum of Understanding to reflect any major changes.

The next stage in program development is project startup, followed by full-scale implementation, both discussed in Chapter 5. No matter how good the program design, the process of startup and full-scale implementation will almost certainly raise a number of unanticipated problems, requiring further revisions of the MOU at later stages.