# Chapter 3—Program Planning

Planning a program that integrates substance abuse treatment with pretrial case processing will vary somewhat across jurisdictions, reflecting the organizational structure of the particular justice system, substance abuse treatment system, and public health system. The program will also reflect the specific legal framework, traditions, personalities, and "local legal culture" of the jurisdiction. Yet every jurisdiction must answer six basic questions when planning a pretrial treatment program:

- Who will be in the planning group?
- How will the planning group work?
- What information is needed to develop policy and shape program goals and objectives?
- Who makes up the program's target population and when during the pretrial process should the intervention happen?
- What treatment and other resources will be used?
- What will be in the Memorandum of Understanding (MOU) that incorporates commitments from all the key stakeholders?

## Who Should Be Involved?

For a pretrial substance abuse treatment program to work successfully, it must have the support-or at least the acceptance-of leaders in the courts, other criminal justice agencies (especially the prosecutor's office and the defense bar), the treatment community, and other institutions. At the county level the level of government at which most trial courts are organized and at which the pretrial stage of criminal case processing usually takes place -- the following stakeholders should be considered for inclusion on a policy or advisory group to plan a pretrial drug treatment program:

- Chief or presiding judges of the general and limited jurisdiction courts
- Prosecutor
- Public defender
- Representative of the private defense bar
- Court administrator
- Case management agency administrator
- Pretrial services agency director
- Chief probation officer/director of community corrections agency
- Sheriff/jail administrator
- Substance abuse treatment professionals
- Major health institutions/hospital director
- Public health agency director
- Social services agencies, including child protective services
- Local school districts, community colleges, and other educational institutions
- Medical services and community mental health providers
- County commission/senior staff (including budget director)
- Victims' rights groups
- Ex-offender/ex-addict groups
- Community anticrime and antidrug coalitions.

In addition to these community stakeholders, there are important State-level stakeholders as well. Individuals with substance abuse disorders frequently move across county lines, so State-level funding and legislative or rule-making support may be necessary. Further, trial courts function within an organizational framework in which State appellate courts (especially States' supreme courts) and the State court administrator's office shape policy and practice at the trial court level. Moreover, funding and coordination of substance treatment programs is centered at the State level in the office of the State Alcohol and Drug Abuse Director (known in the treatment community as the Single State Agency). Other key stakeholders at the State level are likely to include

Chief Justice

- State Court Administrator
- State legislative leaders
- Governor
- State health and social services department heads.

As a practical matter, it is very difficult for a group this large to do detailed planning. However, it is possible to elicit ideas and concerns from all, to take their views into account in shaping initial plans, and to keep them abreast of developments in the planning process. The detailed planning can be done by a smaller, representative group. The composition of such a "subgroup" is likely to vary from jurisdiction to jurisdiction but should certainly include justice system and substance abuse treatment community leaders.

Judges, especially chief and presiding judges, play critical roles in the planning process because the courts, more than any other entity, will link pretrial processing with substance abuse treatment. It is a judge who will make the diversion or "conditional release" decision to place a defendant in the program. Administrative personnel in the court will monitor the defendant's compliance with conditions set by the judge. Also, because they are known as "neutral parties," judges are in a unique position to bring the relevant stakeholders together in the planning committee.

Judges, especially court and presiding judges, have critical roles to play in the planning process because the courts, more than any other entity, will link pretrial processing with substance abuse treatment.

Prosecutors are important stakeholders as well. They shape overall law enforcement policies in their jurisdictions, establishing policies for filing formal criminal charges. For individual cases, prosecutors decide what specific charges to file and recommend conditions of custody or release, acceptable pleas, and components of a sentence. Sometimes they may also manage diversion programs through their own offices.

The defense bar (particularly the public defender's office, if the jurisdiction has one) should also be involved in planning a drug court program. Defense lawyers may well be skeptical about advising their clients to participate in a program that, in terms of its duration and conditions, may seem more onerous than the disposition that would generally occur. Involving defense lawyers will help ensure that the rights and interests of those for whom the program is designed are taken into account.

Substance abuse treatment professionals and the State Alcohol and Drug Abuse Directors (or their representatives) generally do not have specialized expertise in criminal justice issues, but their treatment expertise is essential for planning an effective drug court program. Often, they have experience working with health and social services agencies, and in some jurisdictions they may have a history of working with persons referred to them by the court. They also will be familiar with many of the funding opportunities and constraints relevant to program planning.

## Planning Committee Structure

### Dedication of Committee Members

Planning committee members must commit to meeting regularly throughout the planning period and during the subsequent implementation of the program to exchange information and to consider and decide on specific actions.

### Staffing

The dedication of committee members will be strengthened if support staff services are available to the planning group. Dedicated staffing can help the committee coordinate its activities, develop agendas, keep a record of committee proceedings, gather the data necessary for planning the program and monitoring implementation, help develop specific proposals, and assist in ongoing analysis and administrative support.

How is the planning group staffed? There are at least three possible approaches:

- A staff-level workgroup can be formed, bringing together senior staff members from the court and other agencies represented on the planning committee.
- If the jurisdiction has a planning commission or criminal justice coordinating council, this body can assign staff to the planning committee. Typically, members of these bodies are also in the drug court planning committee and will already know about many of the involved agencies and issues.
- If the court, prosecutor's office, or a treatment provider consortium has initiated planning for the program, staff from that organization could support the stakeholder planning committee. Any of the three approaches, or a mix that includes elements of some of them, may be appropriate for a jurisdiction that is just beginning the planning process.

### Key Tasks

The relationship between the planning committee and the staff will be unique in each jurisdiction, but there are some tasks that every planning group must address. They include

- Describing the substance abuse problem in the jurisdiction and the nature and prevalence of substance abuse among arrestees who are potential "targets" for treatment program intervention
- Identifying target populations and potential points of intervention
- Determining the case management and treatment services that will be needed by target group members and locating potential case management and treatment service providers
- Addressing legal issues, including program eligibility and acceptance criteria
- Establishing the goals for the program, including anticipated outcomes for defendants who participate in the program and the expected systemic improvements
- Ensuring that adequate management information and tracking systems are in place to enable program monitoring and evaluation
- Developing written agreements (Memoranda of Understanding) that reflect the interests of the stakeholders and their commitments to the program.

In carrying out these tasks, some members of the planning group will undoubtedly be more involved than others, because their day-to-day operations will be more directly affected by the plans that are developed. Trial court judges, treatment providers, and staff from the court, the prosecutor's office, the public defender's office, the pretrial services agency, the case management agency, and the jail, all of which will be involved in daily program operations, should be primary resources both in initial planning and in developing the detailed program design that will follow.

Trial court judges, treatment providers, and staff from the court, the prosecutor's office, the public defender's office, the pretrial services agency, the case management agency, and the jail all should be involved in planning and developing the program.

## Information Needed for Program Planning

Both the policy-level leaders on the planning committee and the staff members involved in planning need several types of information about the jurisdiction to plan effectively. These include information about

- The potential target groups
- The type and number of defendants appropriate for diversion to treatment
- A case management agency
- Available treatment services
- The legal framework including any legal constraints that could affect program design and operation
- Costs
- Facilitation.

### Information About Potential Target Group Members

Planners must be able to identify appropriate categories of defendants to be targeted for treatment intervention. This involves information about resources and political realities, as well as arrestees' characteristics and treatment needs. Specific questions to be addressed should include

- How much pretrial jail space is currently occupied by persons who have substance abuse problems, but who do not have a history of committing violent or predatory offenses? Is jail-based treatment available for pretrial defendants? If not, would it be feasible to start a jail-based program?
- To what extent do defendants released before trial have substance abuse problems? What is the frequency distribution by offense category?
- What characteristics of pretrial defendants would be considered positive indicators for participation in a pretrial substance abuse treatment program? What is the distribution by custody status and offense category? How many defendants fall into these categories in the course of a year?
- What prior criminal history or other defendant characteristics do key stakeholders view as preemptively excluding a defendant from program participation?

Of the defendants who have substance abuse problems and who might be considered for participation in a pretrial substance abuse treatment program

- What is the distribution of the substance abuse problems (including types of substances abused and levels of severity of abuse)?
- What is the frequency and severity of other health problems such as TB, hepatitis, human immunodeficiency virus/acquired immunodeficiency syndrome, and other sexually transmitted diseases?
- What are the demographics that could affect program design (such as age, gender, ethnicity, geographic location in the jurisdiction, employment status/earning capacity, housing, and family situation)?
- Possible sources of quantitative and qualitative data to help answer these questions include
- Police departments
- Sheriff's office/jail administrator
- Pretrial services agency
- Arrestee interviews
- Court records
- Observation/breath and urine testing of arrestees
- Treatment and public health agencies
- Community anti-drug coalitions
- Single State substance abuse agency databases
- TASC or other case management agencies
- Local college and university researchers
- Other criminal justice system practitioners, prosecutors, defense lawyers, judges, probation department personnel.

### Information About Existing Treatment Resources

Drug court planners need to know about the treatment resources (including detoxification facilities) that currently exist in the community, the services that are provided to specific types of clients, and the gaps that exist in provision of services.

Planning committee members familiar with the community's treatment system can help with this inventory, as can the office of the State Alcohol and Drug Abuse Director. Both public and private providers should be included in information-gathering efforts, and the inventory should cover ancillary services that, even though they may not be provided directly by a substance abuse treatment professional, are important for addressing client needs. The planning committee can poll the treatment community by sending a questionnaire to all community providers asking, among other things, what type of services they provide and how willing they are to work with clients in new ways. Responses to the questionnaire help determine interest as well as a compile an inventory of providers.

The committee should clearly identify the size, philosophy, and special characteristics of every existing substance abuse treatment program in the jurisdiction. Some treatment providers may already have specific services in place that would provide a good match for potential target populations drawn from the pool of pretrial defendants. For example, special programs may already exist for women with substance abuse problems.

From a political or criminal justice viewpoint, it is possible that the public health activities in which some treatment providers participate could exclude them from participation in a pretrial drug treatment program. For example, some providers might espouse or operate needle exchange programs that could generate negative publicity or strong community objections. While no hard and fast rules for inclusion or exclusion exist, the planning committee must know the operating philosophies and treatment modalities of each treatment provider in order to anticipate problems.

In addition to developing descriptions of each substance abuse treatment provider's programs and philosophies, the planning committee should also inventory the extent to which other services commonly needed for effective substance abuse treatment are available. Research and clinical experience have shown that treatment is most effective when coupled with other interventions that address the full range of client needs. The availability of such ancillary services enables the client to benefit more fully from treatment.

Substance abuse treatment clients are likely to have needs and deficits in one or more of the following areas:

- Education
- Literacy skills
- Life skills (such as parenting)
- Physical and mental health
- Housing
- Vocational training
- Employment
- Child care
- Specific cultural/gender needs
- Legal problems (for example, eviction from housing or suspension or revocation of a driver's license)
- Transportation
- Domestic violence.

In conducting an inventory of programs and services that can supplement the needs of clients in these areas, the planning committee can obtain assistance from substance abuse treatment providers. Treatment providers are increasingly sensitive to the need for these services and can usually provide lists of available community resources. Members of the planning committee who are affiliated with educational organizations and social services agencies can also help identify these resources.

### Information About Legal Issues

In the initial planning stages, there are three types of legal issues about which planners need information:

- To what extent, and in what ways, do existing laws, regulations, and authoritative court decisions either constrain or facilitate program design? For example, is there existing legal authority, either in statute or in court rule, for judges to refer defendants to a treatment program or to make urine testing and participation in a substance abuse treatment program conditions of pretrial release? Conversely, are there any legal prohibitions against such judicial orders?
- What laws and regulations may affect treatment providers' capacity to treat pretrial defendants and to inform the court and other justice system agencies about a client's progress (or lack of progress) in treatment?
- What laws and regulations may affect financing for the program, including laws governing state and local budget processes, federal grant funding, and reimbursement of treatment costs?

Developing an understanding of the legal framework will give planners critical information about specific program design issues. Several of the key legal issues that must be addressed in the planning, program design, and program implementation processes are discussed in Chapter 8 of this TIP.

### Information About Costs

Substance abuse treatment costs money. Reorganization of the operating procedures of courts and other criminal justice agencies to link pretrial processing with substance abuse treatment is also likely to lead to additional costs. Examples of new resources that may be needed include additional staff (to perform functions not previously performed) and new computer equipment to produce the information needed for case decision-making, program monitoring, and evaluation.

The planning committee must have reliable information about all of the costs to be incurred in implementing the program. Optimally, the committee will have information on costs at different levels of operation, from the time of an initial pilot to full-scale operation. The committee should examine what sources of funding are available, both for initial program operations and for ongoing operations if the program proves successful. The committee should also seek to identify the benefits of treatment, both to the community and to the defendant. If possible, estimates of the economic value of these benefits should be developed. Chapter 7 of this TIP discusses cost and financing issues in more detail.

## Determining the Target Population and Possible Points of Intervention

Once the planning committee has developed basic information about the pool of eligible defendants and the treatment resources available, decisions can be made about what categories of defendants will comprise the target population for the program. The size and makeup of the pool of potentially eligible defendants, program costs, politics, and community standards and values are among the factors that must be considered in deciding on a target population.

Drug courts have varied considerably in their choice of target groups. Although some handle only drug possession cases, some accept defendants charged of a much wider range of offenses (usually nonviolent) when the criminal behavior appears to be driven by a substance abuse problem.

Jurisdictions that have started drug courts have varied considerably in their choice of target groups.

Generally, drug courts have excluded defendants charged with sale or trafficking of drugs unless they played a minor role in distribution and an underlying addiction is clearly driving their participation in drug selling. The Superior Court Drug Intervention Project in Washington, D.C., is one of the exceptions: Any felony drug defendant on pretrial release is eligible to participate, regardless of conviction record. (Violent felony defendants, of course, would normally be in detention and would not be in the eligible pool.) The drug court in Portland, Oregon, also accepts defendants with extensive criminal records, including violent offenders, but excludes those charged with drug sales or trafficking. (Note, however, that federal funds are not used for interventions with violent offenders in accord with federal policy.)

Decisions about target group composition will be based in part on what kinds of cases are acceptable from a political standpoint and in part on the needs of the potential target population and the availability of treatment resources. With information about the size and makeup of the potentially eligible groups of defendants, their treatment needs, and existing treatment resources, the planning committee can project the size of the program and the characteristics of the potential participants. Such a projection will help the committee assess the range of needed services and develop criteria for participant selection and treatment services. If the target population is clearly too large or too small, further refinements in the definition of the target group will be required.

Target populations will vary depending on the stages in the process at which the treatment intervention is sought. In general, the earlier in the process the intervention is made, the stronger the rationale for targeting defendants whose current charges and prior records indicate no history of violent offenses or significant drug trafficking. The more serious the current offense and prior record, the greater the likelihood that pretrial and case management staff will want additional information about the defendant's criminal activity and substance abuse. While these defendants may not be automatically excluded from a pretrial drug treatment program, it may be appropriate to ensure that the treatment take place in a secure setting (possibly including jail) or to set conditions that include close supervision while the defendant is on pretrial release.

### Selecting Treatment Providers and Programs

It is pointless to target a specific population for a drug court program if appropriate treatment resources are not available or cannot be developed. The planning committee should carefully consider the resources of the substance abuse treatment system in the community and work closely with the community to design a set of realistic treatment options.

The planning committee's inventory of treatment providers and ancillary services, coupled with an analysis of the target group's treatment needs and information about treatment costs, should provide the basic information necessary to select a primary treatment provider or a network of providers. Sometimes, no existing program in the community will meet the needs of the target population. Under these circumstances, it may be necessary to negotiate with existing providers to modify their services or create new ones. Conceivably, it may even be necessary to ask treatment providers outside the locality to expand their services.

### Creating Memorandum of Understanding

Initial agreements, in the form of a Memorandum of Understanding (MOU), is another critical part of the planning process. The MOU should set forth the goals of the program and should include commitments from all the key stakeholders and planning committee members. The memorandum is contractual in nature and should spell out, to the extent possible, the composition of the target group and the anticipated contributions and responsibilities of each stakeholder that is a party to it.

Development of the MOU is a key transition point from initial planning stage to actual program design. While the contents of a MOU will vary from one jurisdiction to another, essential elements of it should include at least the following:

- A description of program goals
- A description of the target group
- A description of program services to be provided, and how and by whom they will be provided, including
  - Screening
  - Assessment
  - Detoxification
  - Case management
  - Substance abuse treatment
  - Ancillary services.
- A description of program organization and management, including the identity of individuals who will have primary responsibility for program operations within the justice, case management, and treatment systems
- A description of the management information system reports that will be available to support program operations, and the provisions for cross-system exchange of information
- A summary of key measures of program performance to be used for monitoring and evaluation, with sources of relevant data indicated
- A budget showing anticipated expenses and sources of revenue for all program components
- Approvals by the key stakeholders, indicating their commitment to the plan developed thus far
- A description of the processes to be followed in program review and evaluation and in amending the MOU as necessary.