# Chapter 2—Key Elements of Treatment Drug Courts

Successful collaboration among the substance abuse treatment system, the public health system, and the criminal justice system requires that practitioners in each system understand the values and perspectives of the other systems. Effective systems integration depends on practitioners' ability to

- Develop and clearly state shared goals
- Jointly obtain, exchange, and use information
- Engage in ongoing communications about individual cases and systemic issues
- Develop operational procedures that meet the needs of the individuals in treatment and take into account the available resources of the participating institutions
- Perhaps most importantly, exercise strong leadership within each system.

This chapter describes the values and perspectives of each of the collaborating systems and discusses each of the areas listed above. This discussion will help practitioners in all systems integrate substance abuse treatment in the pretrial processing of criminal cases.

## Understanding Each System's Basic Values and Perspectives

Significant differences in the philosophies, activities, and structure of the three systems pose a challenge to collaboration, as do the differences in goals, values, and approaches to specific problems. However, there are some important values that are broadly shared by practitioners who work within the substance abuse treatment, public health, and criminal justice systems.

### Justice System

The justice system is based in law, state and local procedures, and the local legal culture. Courts are at the center of the adjudication process, which in criminal cases is typically adversarial. Charges are brought by a prosecutor on the basis of evidence gathered by the police or another law enforcement agency. The defendant is usually represented by a defense lawyer, required if the charges are serious enough that they could result in incarceration upon conviction. A judge presides over court proceedings in the case. The judge

- Advises defendants of their rights
- Sets conditions of pretrial release
- Conducts hearings and trials and determines guilt or innocence
- Sentences defendants who plead guilty or are found guilty after trial.

The judges, prosecutors, and defense lawyers who work in the criminal courts naturally approach a case involving a substance-abusing individual as a legal matter. The nature of the defendant's substance abuse problem is, if it is discussed at all, a secondary issue. The primary focus is on the defendant's guilt or innocence with regard to the criminal charges that led to arrest and prosecution. The differences between the two types of courts are summarized in Exhibit 2-l.

Exhibit 2-1 Traditional Court Characteristics Versus Drug Court Characteristics

Traditional Court | Drug Court
Court team of judge, prosecutor, defense counsel, etc | New court team created to achieve goals of supportive treatment interventions
Adversarial | Non-adversarial
Goal = Process case; apply the law | Goal = Restore defendant as a productive, non-criminal member of society
Judge exercises limited role in supervision of defendant | Judge plays central role in monitoring defendant's progress in treatment
Interventions for substance abuse at discretion of judge | Formalized and structured treatment interventions
Relapse may lead to increased sentence | Graduated sanctions used to respond to lapses in drug court program conditions

However, while the criminal laws and related public safety concerns are important for justice system practitioners, they are by no means the only values that influence the operation of the system. Other broadly shared goals include

- Due process. Justice system practitioners place a high value on both the appearance and the reality of even-handedness in the administration of justice. This means that defendants charged with the same offense who have similar criminal records and other relevant characteristics in common will be treated in a consistent fashion.
- Protection of individual rights. Defense lawyers have a special role as guardians of a defendant's legal rights. All justice system practitioners are concerned with upholding these rights -- including the right to representation of counsel and the right to make informed choices about available alternative courses of action during the pretrial process.
- Expeditious resolution of cases. The swift resolution of cases is important for victims, defendants, and the public. Systemic delay can undermine the court's credibility, lessen the quality of justice, and impair the court's ability to take on new programmatic initiatives.
- Appropriate disposition. While practitioners with different roles and responsibilities may disagree about the appropriate disposition of a particular case, they tend to view the relative severity of different offenses and appropriate dispositions for particular types of criminal conduct roughly the same way. Of particular relevance for this Treatment Improvement Protocol (TIP), there appears to be an emerging consensus among justice system practitioners that prison is a scarce resource, best used for individuals who are genuine threats to public safety. There is a growing awareness that incarcerating individuals for drug use or possession may not be an effective use of prison space and that substance abuse treatment has a far greater likelihood than incarceration of reducing future criminal behavior by addicted individuals.

Justice system practitioners increasingly view prison as a scarce resource that may not be the best place for those charged with drug use or possession.

### Substance Abuse Treatment System

The treatment system's primary purpose is to end or alleviate a client's substance abuse. Practitioners in the system generally adopt a health promotion/disease prevention model in which the treatment professional works with the client to overcome what is seen as a biopsychosocial disease or disorder. The term biopsychosocial is used to indicate that biological, psychological, and social factors are deeply woven into the development of addiction. These factors must be addressed in order for treatment to succeed. Substance abuse treatment practitioners recognize that some types of substance abuse involve possession and use of illegal drugs, but their primary concern is not with the illegality of the activity; rather it is with the recovery from addiction.

Substance abuse generally becomes more severe over time; if left untreated, the disease can be fatal. Substance use disorders cannot be "cured," but many individuals can make the behavioral changes necessary to recover.

The treatment community recognizes that relapse is a common feature of addiction. Indeed, relapse -- a return to addictive behavior -- may sometimes be a step (or misstep) on the path to recovery, rather than a failure. It is not uncommon for an individual to alternate between treatment and relapse before completely recovering.

Treatment practitioners note that the progression of the severity of substance abuse can be depicted on a continuum that ranges from experimentation at one end to recovery or death on the other. The goals of treatment, which apply to every stage of the continuum, are

- To reduce the incidence and prevalence of the chronic, progressive abuse of alcohol and other drugs
- To provide a system of services to assist people, their families, and communities in recovering from addiction
- To decrease the number of people at risk for addiction.

Matching people to the appropriate level of care and providing a range of support services (for example, medical care, child care, housing, job training, and aftercare) are key elements of the treatment process. Support services allow individuals to make effective use of substance abuse treatment. Careful assessment both of the person's severity of addiction and of the range of problems related to substance use, such as medical illness, family and social problems, legal problems, and lack of adequate housing and nutrition, is critical to client-treatment matching. Successful treatment generally includes some form of supportive, drug-focused individual and/or group counseling to identify relapse triggers and provide long-term support. Self-help groups, such as Alcoholics Anonymous and Narcotics Anonymous, while not considered treatment, help many successfully recover.

Services provided to people at different stages of the disease can be divided into three categories: (1) pretreatment services (prevention, including education about the dangers of substance abuse), (2) outpatient treatment, and (3) inpatient treatment (including residential treatment). Most drug courts target services for persons in the latter two stages, although prevention services may be provided for those who are minimally involved in drug use. For a more detailed description of treatment approaches and modalities, see Chapter 4.

Public health's "big picture" approach contrasts sharply with the justice system's focus on individual clients or defendants.

### Public Health System Values and Perspectives

Public health practitioners are focused on the health of entire communities. Indeed, public health can be defined as organized community activities that promote the improvement of physical, occupational, behavioral, and social health. The public health system is grounded in an epidemiological approach that studies the determinants of disease and health risks, their distribution, and the incidence of disease across and within population subgroups. It is a "big picture" approach quite different from the focus on individual clients or defendants that is characteristic of many substance abuse treatment and justice system practitioners.

Public health goals include health promotion and disease prevention, which depend on the interrelationship of health and social service agencies. The early stages of criminal case processing present a valuable point of public health intervention, because many people arrested have substance abuse problems accompanied by infectious disease. Well-designed screening to identify criminal defendants with substance abuse problems can also help identify defendants who have HIV/AIDS, other sexually transmitted diseases (STDs), TB, and hepatitis B. Referral to treatment will not only help such defendants, it will also help prevent further spread of these diseases.

The early stages of criminal case processing present a valuable point of intervention, because many who are arrested have substance abuse problems accompanied by infectious diseases.

### Addressing Value Conflicts

Values inherent in one of the three systems sometimes conflict with those of another. For example, two of the best-known harm reduction strategies advocated by some public health professionals are needle exchanges for addicts and condom distribution, both designed to prevent the spread of HIV and other sexually transmitted diseases. Many people within justice agencies believe these public health programs condone illegal drug use.

Similarly, some substance abuse treatment programs have a "controlled use" orientation. A provider in such a program may condone or even applaud a client moving to a lower level of drug use or reducing frequency of use. However, when the drug being used is an illicit one, a controlled use orientation may be unacceptable to criminal justice agencies.

Problems can arise when courts, criminal justice agencies, and other public institutions form partnerships with treatment agencies and adopt harm reduction strategies that are not acceptable to some groups in the community. Such situations can be difficult for justice system leaders, especially if the goals and operational procedures of all the partners are not clearly understood before agreements are signed.

## Developing Shared Goals

Given the range of values and philosophical world-views, it is critical that leaders in each system understand each other's values, perspectives, and priorities. Only then can policymakers and practitioners develop a set of shared goals. The process of developing shared goals compels policymakers to think through the reasons for instituting the program, assess what can be accomplished with the available resources, and consider what structural and procedural changes may be necessary for the success of the program. The potential benefits of integrating substance treatment with pretrial case processing can be a starting point for developing shared program goals.

Following are the five goals of collaborations among the treatment, justice, and public health systems:

- Reduced criminal behavior: fewer repeat offenders
- Better use of limited jail space: fewer addicted prisoners and more jail space for those who pose public safety risks
- Improved delivery of treatment services: more effective treatment for a significant population of substance abusers
- Effective disease prevention and treatment: better health status for substance abusers as well as prevention and treatment of infectious diseases
- Improved productivity: greater employment and reduced dependence on social services and health systems.

## The Key Role of Information

In setting goals and developing program structure and operational procedures, planners need frequently updated information from all three systems -- the justice system, the treatment system, and the public health system.

Timely and accurate information is especially important for programs that provide treatment intervention in the pretrialstages of criminal cases. The immediate post-arrest period is a time when critical justice system decisions are made about a defendant, including decisions about specific charges to be filed, conditions of custody or release, and appointment of defense counsel. To enroll a person who has been arrested in a substance abuse treatment program, everyone involved -- especially the court, the prosecutor, the defendant, and defense counsel, and the treatment provider -- will need accurate information on some key topics:

- The nature and circumstances of the current charge
- The defendant's criminal record
- The status of any pending cases
- The nature and severity of the defendant's substance abuse problem(s)
- The defendant's treatment history
- The defendant's mental and physical condition, including the presence of any infectious diseases
- Based on the information gathered, the availability of a treatment "slot" appropriate for the defendant.

Obtaining such information can be a challenge under any circumstances, and it is a major challenge to do so in the 24- to 72-hour period advocated by proponents of rapid treatment intervention. However, as a number of jurisdictions have demonstrated, it is possible. According to a recent American University survey, the following treatment drug courts screen dependents within 72 hours and begin assessment and treatment intervention within 1 day: District of Columbia (Superior Court); Fort Lauderdale, Florida; Kalamazoo, Michigan; Las Vegas, Nevada; Seattle, Washington; and Kansas City. It is also possible to design information systems that give everyone involved quick access to information on defendants' performance in treatment and their compliance with other conditions of release set by the court. This rapid transfer of information allows both systems to manage cases and interested parties to follow the program's and individuals' progress.

Traditionally neither courts, criminal justice agencies, nor substance abuse treatment providers have shared information like this, so they must all move forward carefully. Information transfer must abide by confidentiality laws designed to protect privacy of individuals (see Chapter 8), and it may require investment in computer hardware and software. When the commitment to share information is made, as it has been in some jurisdictions, the benefits -- in terms of sound program management and informed decision-making -- are enormous.

## Leadership

In studies of corporate and public sector innovation and excellence, effective leadership consistently emerges as a critical factor. It will undoubtedly be a key factor in the success of any program aimed at integrating substance abuse treatment with pretrial case processing.

In this context, it is important to emphasize the necessity of collaborative leadership. While individual judges and prosecutors led the way in establishing most of the successful the drug court programs, they were supported by a wide range of individuals in top and middle management positions in the courts, other justice system agencies, the treatment community, and other public and private institutions.

Leadership in this area is not limited to the top managers of the institutions involved. There is plenty of room for leadership at middle management levels, too -- in the courtroom, in treatment clinics, in public health agencies, and in the broad array of criminal justice, educational, and social services agencies that become involved in a comprehensive approach to treating the substance abuse problems of defendants in criminal cases.