# Chapter 1—Introduction

Substance abuse is a long-standing problem in American society, one closely linked to societal problems from dysfunctional families and child abuse and neglect to unemployment, economic underdevelopment, and crime. The numbers of Americans who abuse alcohol and other drugs are staggering. During any given month during the last 20 years, at least 14 million and sometimes as many as 25 million Americans used some type of illicit drug (Gerstein and Harwood, 1990). Recent conservative estimates indicate that about 17 million Americans suffer from some form of alcoholism or alcohol abuse National Institute on Alcohol Abuse and Alcoholism, 1993).

While drug-related cases have long been part of the caseloads of the Nation's courts and other criminal justice agencies, substance abuse problems recently have inundated the courts. In the late 1980s, as law enforcement agencies implemented or expanded strategies that emphasized the arrest and prosecution of users and street-level dealers, drug-related felony cases piled up in the courts. The increased volume of cases, coupled with the enactment of laws by the Federal Government and many States that require mandatory terms of imprisonment for drug-related offenses, produced a sense of crisis in many American courts. For example, according to the report of a 1989 conference attended by court system leaders from the Nation's nine most populous States, "the general sense was that most trial courts are being overwhelmed by drug cases." Conferees warned of "either an imminent or existing caseload crisis and possible breakdown of the system if solutions are not found soon" (Lipscher, 1989). The well-documented increase in jail and prison populations around the Nation is directly attributable to the upsurge in the prosecution of drug charges and related crimes fueled by drug abuse.

The search for solutions has led State and local jurisdictions to try a variety of approaches in handling drug-related cases. One of the most innovative approaches is integrating substance abuse treatment with the pretrial processing of criminal cases. These programs are known as "drug courts" or "treatment drug courts." No two of these programs are exactly alike, but common threads run through them all.

While drug-related cases have long been part of the caseloads of the Nation's courts and other criminal justice agencies, recent developments have made substance abuse problems a pressing concern of the courts.

## What Are Treatment Drug Courts?

While they vary widely in scope, organization, and points of intervention, all the treatment drug courts developed in recent years share an underlying premise that drug possession and use is not simply a law enforcement/criminal justice problem but a public health problem with deep roots in society. All of these drug court programs see the court, and specifically the judge, as filling a role that goes beyond that of adjudication.

In drug court programs, criminal justice agencies collaborate closely with the substance abuse treatment community and other societal institutions to design and operate the program. As Goldkamp (1993) describes in his report of the first National Drug Court Conference, "These courts rely on strong collaboration among judges, prosecutors, defense lawyers and related supporting agencies (such as case management, corrections, pretrial services, probation, etc.), on the one hand, and a partnership with treatment agencies (or providers) and other community organizations and representatives on the other." These programs are based on an understanding that substance abuse is a chronic, progressive, relapsing disorder that can be successfully treated. The success of these programs is built on the fact that the post-arrest period can provide a particularly good opportunity for interventions that will break the drug-crime cycle.

Most programs incorporate the following key principles recommended in legislation developed by the President's Commission on Model State Drug Laws:

- Early identification of defendants in need of treatment and referral to treatment as soon as possible after arrest
- Early and professional diagnosis of defendant's treatment needs
- Matching those needs to specific treatment programs
- Making treatment a court-monitored requirement and providing for judicial review and supervision of the defendant's progress in treatment
- Holding defendants accountable through a series of graduated sanctions and rewards
- Providing aftercare and support services following treatment completion.

Drug court programs involve the close collaboration of the criminal justice system with the substance abuse treatment community and with other societal institutions.

## Potential Benefits of Systems Integration

The recognition that treatment works -- not in every case, but often enough to make treatment-oriented drug courts a better alternative than conventional case processing for some defendants -- is a key operating premise of drug courts. However, for treatment to work, a number of individuals and institutions must cooperate and collaborate.

When collaboration among systems works well, the benefits to individuals and to society can be enormous. For drug-involved defendants, the possible benefits of effective collaboration include

- Improved physical and mental health, including recovery from addiction
- The opportunity for education and employment
- Improved social functioning
- The opportunity to become a productive member of society
- A favorable disposition of a court case (such as dismissal or significant reduction of the charges).

The court system benefits because of the effective disposition of many drug cases and because caseload pressures are eased, allowing the system more time for non-drug cases.

For society, the possible benefits of effective collaboration include

- Reduction in criminal behavior
- An improved workforce
- Reduction in spread of substance abuse-related diseases
- Reduced medical costs
- Reduction in incarceration costs.

The public health benefits of effectively integrating substance abuse treatment and criminal case processing are especially important. A high proportion of the defendants in criminal cases have substance abuse problems. Some defendants already have one or more of the infectious diseases often associated with substance abuse, such as human immunodeficiency virus/acquired immunodeficiency syndrome (HIV/AIDS), tuberculosis (TB), and hepatitis.

Defendants with compromised immune systems are at risk of acquiring TB, especially if they are confined in crowded jails after arrest. The drug court process can help identify defendants who have contagious diseases and thus prevent the spread of disease. The screening process can also uncover defendants' underlying mental health problems, which may be contributing to interpersonal and family violence.

Programs integrating substance abuse treatment with justice system case processing offer many opportunities for court system leaders, trial court judges, and other justice system practitioners who handle substance abuse-related cases. They can break new ground, help shape policies and practices that will improve the lives of people who are involved in criminal cases, and help forge new relationships among courts, substance abuse treatment providers, public health agencies, and other societal institutions. The challenge is to do so in a fashion that is consistent with fundamental principles of fairness and due process of law.

The benefits to society include reduction in criminal behavior, an improved work force, improved social functioning of defendants, reduction in the spread of substance abuse-related disease, and reduced medical costs.

Drug courts first appeared in 1989 and have multiplied since 1992. In 1996, over 125 drug courts were operating in 45 States and more than 100 jurisdictions, and 24 were being developed. At least 25 had operated for two years or more, supervising an estimated 20,000 participants.

The collaborative planning, program design, and implementation that have taken place already in the fledgling drug courts prove that integration of substance abuse treatment and justice system case processing is feasible. A study of the Miami Drug Court (the first in the nation) conducted for the National Institute of Justice found both success in treatment and reduced re-arrests among defendants processed in treatment-oriented drug courts.

The researchers focused on defendants over an 18-month period and compared them to similar defendants not in the program. They found that among Drug Court defendants, there were

- Fewer cases dropped
- Lower incarceration rates
- Less frequent arrests
- Longer times before subsequent re-arrests
- Higher failure-to-appear rates, caused mainly by the more frequent appearances required of Drug Court defendants(Goldkamp and Weiland, 1993).

## Scope and Objectives of This TIP

This Treatment Improvement Protocol (TIP) focuses on the integration of substance abuse treatment with criminal justice system operations during the pretrial stages of criminal cases. Although these are the boundaries of the discussion in this TIP, we recognize that some treatment drug courts work with post-adjudicated individuals as opposed to individuals in the pretrial phase of the criminal justice system. TIP 12 in this series, Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System (CSAT, 1994d), focuses on post-adjudication treatment options for offenders, that is, those who have been found guilty.

The consensus panel for this TIP recognizes that not all treatment programs or all substance-abusing individuals can be neatly categorized as either "pretrial" or "post-adjudication." The treatment drug court concept started as an identifiable package of clear elements that has been adapted to fit local circumstances; different locations have attempted to address similar issues in different ways. Many substance abuse treatment programs that accept court referrals handle both pretrial defendants and sentenced offenders. It is also possible for an individual to be in more than one category at one time. For example, an offender could be participating in a substance abuse treatment program as a condition of probation following conviction on one offense and become a pretrial defendant by being arrested on a new charge.

There are, however, some unique aspects to the linkage between substance abuse treatment and the pretrial processing of criminal cases. Defendants who have been arrested but not yet convicted are legally presumed innocent and cannot be compelled to participate in a treatment program. A judge can, however, exercise significant authority over pretrial defendants, including ordering drug testing and treatment as conditions of release from pretrial detention. The authority of the judge to establish conditions of pretrial release and to defer prosecution or sentencing is critically important for the development of programs linking substance abuse treatment and pretrial case processing.

The adoption of pretrial intervention also has implications for decisions on who is targeted for intervention; for the nature and timing of screening and assessment activities; for sanctions imposed for noncompliance; and for many other program design and implementation issues. For example, a program that dismisses the charges of those who complete community-based drug treatment could apply to only those defendants whose current charges do not involve violence or other offenses imprisonable upon conviction. And, because treatment is to be initiated and monitored during the pretrial process, a great deal of information about the defendant must be acquired and processed quickly to make an informed decision on program admission. This puts a premium on accurate and reliable information and on the ability of criminal justice agencies, courts, substance abuse treatment providers, and public health services to exchange information quickly.

A pretrial defendant cannot be compelled to participate in a treatment program: The decision to participate is the defendant's.

## The Diversity of Drug Court Models

There is no single model for the integration of treatment and pretrial case processing; jurisdictions have developed a wide range of drug court models. Among them are

- Use of "supervised release" or "conditional release" mechanisms, in which the defendant is released from pretrial custody under conditions that include regular or random urine screening and participation in a substance abuse treatment program
- Acceptance into a treatment program shortly after arrest, with an understanding that (a) further prosecution will be held in abeyance; (b) if the defendant successfully completes the program, the charges will be dismissed; and (c) if the defendant does not complete the program, prosecution will go forward on the original charge.
- Acceptance into a "deferred judgment" program or "post-plea diversion" program shortly after arrest, under which the defendant pleads guilty to a criminal charge (for example, unlawful possession of drugs) with the understanding that (a) sentence will be deferred; (b) if the defendant successfully completes the program, the plea of guilty will be vacated and the charges dropped; and (c) if the defendant fails to complete the program, sentence will be imposed on the original charge.
- Use of jail-based treatment programs for pretrial defendants who are not released from custody and for defendants participating in a conditional release, diversion, or deferred adjudication treatment program who relapse into using alcohol or illegal drugs.

Some examples from drug courts are provided inExhibit 1-1.

Exhibit 1-1 Examples of Systems Integration

In the District of Columbia and Multnomah County, Oregon, "supervised release" or "conditional release mechanisms" operate to release defendants from pretrial custody under conditions that include regular or random urine testing, graduated sanctions, and participation in a substance abuse treatment program."
The Dade County, Florida, program involves acceptance into a drug court treatment program shortly after arrest, with an understanding that further prosecution will be held in abeyance, and if the defendant successfully completes the program, the charges will be dropped.
Pensacola, Florida has a "deferred judgment" program or "post-plea diversion" program shortly after arrest, under which the defendant pleads guilty to a criminal charge (for example, unlawful possession of drugs) with the understanding that sentence will be deferred. If the defendant successfully completes the program, the plea of guilty will be vacated and the charges dropped, but if the defendant fails to complete the program, sentence will be based on the original charge.

## The Purpose of This TIP

The primary objective of this TIP is to help policymakers and practitioners plan, implement, monitor, and evaluate programs that integrate substance abuse treatment with the pretrial processing of criminal cases.

The TIP does not advocate one type of program model. It does emphasize the integration of court processing and treatment services common in most recently developed programs. In those collaborative drug courts, a defendant's case is generally diverted from the usual course of prosecution, but the court monitors the defendant/client's treatment progress along with the clinician. With input from the treatment provider, the judge may impose sanctions (consequences) when it is apparent that the defendant has failed to comply with program requirements. By the same token, the judge may "reward" progress by making conditions of release less stringent or by publicly acknowledging an individual's progress in open court. The result is a much stronger and more active partnership between the justice system and the treatment community than existed in earlier diversion programs.

This TIP has been developed by a panel of practitioners from a number of different disciplines and different jurisdictions, almost all of whom have had first-hand experience with such integrated programs. Panel members believe that this kind of systems integration has great potential for improving the quality of justice and the effectiveness of substance abuse treatment. The document is intended to assist other practitioners in conceptualizing, planning, and implementing programs that will work for their jurisdictions.

## Organization of This TIP

The remaining seven chapters address the key issues involved in planning, implementing, and evaluating programs that integrate substance abuse treatment and pretrial case processing.

Chapter 2, "Key Elements of Treatment Drug Courts," describes critical components of effective multisystems integration, taking account of the goals and perspectives of the justice system, the treatment community, and the public health system.

Chapter 3, "Program Planning," describes the initial formation of a planning committee and its activities, especially in regard to early policy decisions such as selecting the target population.

Chapter 4, "Designing the Program," focuses on nine key sets of operational issues, such as screening and assessment, that must be addressed in designing the day-to-day operations of the program. The chapter includes a broad overview of the range of substance abuse treatment modalities and the components that constitute effective treatment. Another section describes types of diversion programs already in existence and discusses the roles of the judge, prosecutor, defense counsel, and other practitioners involved in programs that integrate substance abuse treatment and pretrial case processing.

Chapter 5, "Implementation," focuses on staff training and education, public relations, and other issues that may arise in the pilot period of the program.

Chapter 6, "Program Evaluation," addresses evaluation strategies and techniques.

Chapter 7, "Program Costs and Financing," focuses on identifying program costs and developing funding sources. Approaches to estimating costs and benefits are described.

Finally, Chapter 8, "Legal and Ethical Issues," discusses such issues as they arise in providing substance abuse treatment to defendants during the pretrial stages of a criminal case.

## Endnote

Information about the drug court experiences is drawn from a variety of documents, many of which are in the collection of The Bureau of Justice Assistance Drug Court Resource Center at American University School of Public Affairs. See especially Cooper, Caroline, An Overview of Operational Characteristics and Implementation Issues and Cooper, Caroline, and Joseph Trotter, Drug Case Management and Treatment Intervention in the State and Local Courts, Volumes I and II, published by American University in 1995. See also John S. Goldkamp, Justice and Treatment Innovation: The Drug Court Movement "A working paper of the First National Drug Court Conference December 1993", a report on the First National Drug Court Conference published by the National Institute of Justice and the State Justice Institute.