# Appendix C—Federal Resource Panel

- Peter J. Delany, D.S.W.
- Social Science-Analyst
- Treatment Research Branch
- Division of Clinical Research National Institute on Drug Abuse

- Terrance Farley
- Director
- National Drug Prosecution Center
- National District Attorney's Association

- D. Alan Henry
- Executive Director
- Pretrial Services Resource Center
- Washington, DC

- Sandra H. Kerr
- Public Health Analyst
- Office of the Deputy Director for HIV National Center for Prevention Services Centers for Disease Control

- Geoffrey Laredo, M.P.A.
- Senior Program Analyst
- Division of Planning and Policy Implementation
- Office of the Policy and Program Coordination Center for Substance Abuse Treatment

- Barry Mahoney, LL.B., Ph.D. - Co-Chair
- President
- The Justice Management Institute
- Denver, CO

- Charles Messmer
- American Jail Association

- Roberta Messalle
- Senior Adviser, Criminal Justice Linkages
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Janice Munsterman
- Program Manager
- State Justice Institute
- Alexandria, VA

- Barbara T. Roberts, Ph.D.
- Policy Analyst, Demand Reduction
- Office of National Drug Control Policy
- Executive Office of the President

- Kenneth Wayne Robertson
- Public Health Adviser
- Criminal Justice Systems Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment

- Maria E. Schmidt
- Policy Analyst
- National Center for State Courts
- Arlington, VA

- Kevin M. Sherin, M.D., M.P.H. - CO-CHAIR
- Family Practice Center
- EHS Christ Hospital and Medical Center
- Oak Lawn, IL

- Barbara E. Smith, Ph.D.
- Office of Criminal Justice
- American Bar Association
- Washington, DC

- John Spevacek
- Program Manager
- National Institute of Justice
- Department of Justice
- Washington, DC