# Appendix A -- Bibliography

Agopian, M.W. Politics of evaluating diversion programs. Evaluation Quarterly. 1979;3(1):81-88.
Ali, B.E. The International Prisoners Aid Association and drug abuse control. Bulletin on Narcotics. 1991;43(1):3-7. [pmid: 1667900].
American Prosecutors Research Institute, National Drug Prosecution Center and the Bureau of Justice Assistance. Beyond Convictions. Prosecutors as Community Leaders in the War on Drugs. Chapter 4: Diversion to Treatment. 1993.
Annas, G.J. Control of tuberculosis:the law and the public's health. New England Journal of Medicine. 1993;328(8):585-588. [pmid: 8426636].
Belenko, S. and Dumanovsky, T. Special drug courts: program brief. Washington, DC: Bureau of Justice Assistance; 1993.
Bickell, N.A., Vermund, S.H., Holmes M., Safyer, S., and Burk, R.D. Human papillomavirus, gonorrhea, syphilis, and cervical dysplasia in jailed women. American Journal of Public Health. 1991;81(10):1318-1320. [pmid: 1928533].
Brochu, S. and Levesque, M. Treatment of prisoners for alcohol or drug abuse problems. Alcoholism Treatment Quarterly. 1990;7(4):113-121.
Brownstone, D.Y., and Swaminath, R.S. Violent behaviour and psychiatric diagnosis in female offenders. Canadian Journal of Psychiatry. 1989;34(3):190-194.
Bureau of Justice Assistance. Differentiated Case Management. Bureau of Justice Assistance Fact Sheet. Washington, DC: Bureau of Justice Assistance; Nov 1995.
Califano, J.A. The Three-Headed Dog from Hell: The Staggering Public Health Threat Posed by AIDS, Substance Abuse, and tuberculosis. Washington Post, December 21, 1992, p. A21.
California Center for Judicial Education and Research. Drug Courts: A Judicial Manual. California Center for Judicial Education and Research; Summer 1994, pp. 16-17.
Center for Substance Abuse Treatment. Screening and Assessment of Alcohol- and Other Drug-Abusing Adolescents. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 93-2009; 1993a. Treatment Improvement Protocol (TIP) Series 3.
Center for Substance Abuse Treatment. Screening for Infectious Diseases Among Substance Abusers. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 93-2048; 1993b. Treatment Improvement Protocol (TIP) Series 6.
Center for Substance Abuse Treatment. Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 94-2076; 1994 a. Treatment Improvement Protocol (TIP) Series 7.
Center for Substance Abuse Treatment. Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 94-2078; 1994 b. Treatment Improvement Protocol (TIP) Series 9.
Center for Substance Abuse Treatment. Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 94-2094; 1994 c. Treatment Improvement Protocol (TIP) Series 11.
Center for Substance Abuse Treatment. Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 94-3004; 1994 d. Treatment Improvement Protocol (TIP) Series 12.
Center for Substance Abuse Treatment. Detoxification from Alcohol and Other Drugs. Rockville, Maryland: Center for Substance Abuse Treatment, U.S. Department of Health and Human Services publication SMA 95-3046; 1995 . Treatment Improvement Protocol (TIP) Series 19.
Centers for Disease Control and Prevention. Initial Therapy for Tuberculosis in the Era of Multidrug Resistance: Recommendations of the Advisory Council for the Elimination of Tuberculosis. Journal of the American Medical Association. 1993;270(6):694-698. [pmid: 8336361].
Chicago Health Policy Research Council. Analysis of the Structure of State Medicaid Managed Care Programs. Chicago, IL: Chicago Health Policy Research Council; May 1994.
Covell, R.G., et al. Prison experience of injecting drug users in Glasgow. Drug and Alcohol Dependence. 1993;32(1):9-14. [pmid: 8486087].
Dignan, J. Repairing the damage: Can reparation be made to work in the service of diversion?. British Journal of Criminology. 1992;32(4):453-472.
Dubler, N.N. and Sidel, V.W. On research on HIV infection and AIDS in correctional institutions. The Milbank Quarterly. 1989;67(2):171-207. [pmid: 2630900].
Du Toit, L. and Duckitt, J. Psychological characteristics of over- and undercontrolled violent offenders. The Journal of Psychology. 1990;124(2):125-141. [pmid: 2187978].
Dutton, D.G., and Hart, S.D. Risk markers for family violence in a federally incarcerated population. International Journal of Law and Psychiatry. 1992;15(1):101-112. [pmid: 1582739].
Finn, P. and Newlyn, A.K. Dade County Diverts Drug Defendants to Court-Run Rehabilitation Program. In Miami's Drug Court: A Different Approach. Washington, DC: National Institute of Justice; June 1993.
Fraboni, M., Cooper, D., Reed, T.L., and Saltstone, R. Offense type and two-point MMPI code profiles: discriminating between violent and nonviolent offenders. Journal of Clinical Psychology. 1990;46(6):774-777. [pmid: 2286669].
Friday, P.C., Malzahn-Bass, K.R., and Harrington, D.K. Referral and selection criteria in deferred prosecution. British Journal of Criminology. 1981;21(2):166-172.
Gerstein, D.R., Harwood, H.J. The effectiveness of treatment. In: Institute of Medicine, Treating Drug Problems. Washington, DC:National Academy Press; 1990.1:132-199.
Goldkamp, J. Justice and Treatment Innovation: The Drug Court Movement. Washington, DC: National Institute of Justice and the State Justice Institute; December 1993.
Goldkamp, J.S. and Weiland, D. Assessing the Impact of Dade County's Felony Drug Court. Washington, DC: National Institute of Justice; 1993.
Gottheil, D.L. Pretrial diversion: a response to the critics. Crime and Delinquency. 1979;65-75.
Grobsmith, E.S. and Dam, J. The revolving door: substance abuse treatment and criminal sanctions for Native American offenders. Journal of Substance Abuse. 1990;2(4):405-425. [pmid: 1967013].
Health Care Financing Administration, Medicaid Bureau. National Summary of State Medicaid Managed Care Programs. Washington, DC: U.S. Department of Health and Human Services; June 30, 1993.
Heilbrun, A.B., Jr. The measurement of criminal dangerousness as a personality construct: further validation of a research index. Journal of Personality Assessment. 1990;54(1-2):141-148.
Heimberger, T.S., et al. High prevalence of syphilis detected through a jail screening program: A potential public health measure to address the syphilis epidemic. Archives of Internal Medicine. 1993;153(15):1799-1804. [pmid: 8333816].
Inciardi, J.A., et al.
Johnsen, C. Tuberculosis contact investigation: two years of experience in New York City correctional facilities. American Journal of Infection Control. 1993;21(1):1-4. [pmid: 8442516].
Kirk, A. The prediction of violent behavior during short-term civil commitment. Bulletin of the American Academy of Psychiatry Law. 1989;17(4):345-353.
Lake, E.S. An exploration of the violent victim: experiences of female offenders. Violence and Victims. 1993;8(1):41-51. [pmid: 8292564].
Leukefeld, C.G. and Tims, F.R. Drug abuse treatment in prisons and jails. Journal of Substance Abuse Treatment. 1993;10(1):77-84. [pmid: 8383776].
Lipscher, R.D. The Judicial Response to the Drug Crisis: Report of an Executive Symposium Involving Judicial Leaders of the Nation's Nine Most Populous States. State Court Journal. 1989;13:13-14.
McKay, J.R., Murphy, R.T., McGuire, J., Rivinus, T.R., and Maisto, S.A. Incarcerated adolescents' attributions for drug and alcohol use. Addictive Behaviors. 1992;17(3):227-235. [pmid: 1636470].
National Association of Pretrial Services Agencies. Performance Standards and Goals for Pretrial Release and Diversion. Position paper. Washington DC: National Association of Pretrial Services Agencies, August 1978.
Patel, K.K., Hutchinson, C., and Sienko, D.G. Sentinel surveillance of HIV infection among new inmates and implications for policies of corrections facilities. Public Health Reports. 1990;105(5):510-514. [pmid: 2120729].
Peters, R.H., and Kearns, W.D. Drug abuse history and treatment needs of jail inmates. American Journal of Drug and Alcohol Abuse. 1992;18(3):355-366. [pmid: 1415086].
President's Commission on Model State Drug Laws. Vol. IV. Model Criminal Justice Treatment Act. Washington, DC: The White House; 1993: G-141-149.
Prochaska, J.O., DiClemente, C.C., and Norcross, J.C. In search of how people change: applications to addictive behaviors. American Psychologist. 1992;47(9):1102-1114. [pmid: 1329589].
Rebovich, D. Evaluation of deferred prosecution programs. Washington, DC: Bureau of Justice Assistance.
Robles, R.R., Marrero, C.A., Freeman, D.H., Colon, H.M.; Matos, T.D., and Sahai, H. Incarceration history as a risk factor for HIV infection among Puerto Rican injection drug users. Puerto Rican Health Science Journal. 1993;12(1):13-17.
Rosenberg, M.L., O'Carroll, P.W., and Powell, K.E. Let's be clear - violence is a public health problem. Journal of the American Medical Association. 1992;267(22):3071-3072. [pmid: 1588723].
Rosenthal, M.S. The therapeutic community: exploring the boundaries. British Journal of Addiction. 1989;84:141-150.
Smith, B.E., Davis, R.C., and Goretsky, S.R. Strategies for Courts to Cope with the Caseload Pressures of Drug Cases: Executive Summary. Chicago IL: American Bar Association; 1991.
Stevens, N.M. Diversion to treatment background information. Washington DC: Bureau of Justice Assistance, U.S. Department of Justice.
Thorne, S. Education the main weapon as prison officials defend against AIDS threat. Canadian Medical Association Journal. 1992;146(4):573-580. [pmid: 1472173].
Turnbull, P.J., Dolan, K.A., and Stimson, G.V. HIV testing, and the care and treatment of HIV positive people in English prisons. AIDS Care. 1993;5(2):199-206. [pmid: 8329483].
van Hoeven, K.H., Stoneburner, R.L., and Rooney, W.C. Drug use among New York City prison inmates: a demographic study with temporal trends. International Journal of the Addictions. 1991;26(10):1089-1105. [pmid: 1743812].
Viadro, C.I. and Earp, J. AIDS education and incarcerated women: a neglected opportunity. Women & Health. 1991;17(2):105-117.
Vigdal, G. Comprehensive assessment, diagnosis and classification: treatment matching of substance abusing offenders. National Advisory Commission on Criminal Justice Standards and Goals (1973) Report on Corrections. Washington DC: U.S. Department of Justice; 1973: 352-357.
Weiner, J. and Anno, B.J. The crisis in correctional health care: the impact of the National Drug Control Strategy on Correctional Health Services. Annals of Internal Medicine. 1992;;117(1):71-75. [pmid: 1596049].