# Consensus Panel

Chair
- Ira J. Marion, M.A.
- Associate Executive Director, Division of Substance Abuse
- Albert Einstein College of Medicine
- of Yeshiva University
- Bronx, New York

Facilitators
- Sharon R. Dow
- M.S. Chief, Program Planning and Policy Development
- Maryland Alcohol and Drug Abuse Administration
- Baltimore, Maryland
- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates
- San Antonio, Texas
- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center
- Beverly Hills, California

Workgroup Members
- Hope Bolger, R.Ph.
- Methadone Services Consultant
- Department of Mental Health, Mental Retardation and Substance Abuse Services
- Office of Substance Abuse Services
- Richmond, Virginia
- Richard Christensen, P.A., C.A.S.
- Director of Medical Services
- Valle del Sol
- Phoenix, Arizona
- Eugenia Curet, M.S.W.
- Administrator, Adult Methadone Clinic
- The New York Hospital
- New York, New York
- Robert S. Geissinger, C.C.D.C. III
- Certification Specialist, Certification Section
- Division of Alcohol and Substance Abuse
- Department of Social and Health Services
- Lacey, Washington
- Michael G. Hayes, M.D.
- Medical Director
- Man Alive Research, Inc.
- Baltimore, Maryland
- Nancy Jane Heilman, M.S.
- Program Manager, Division of Substance Abuse
- New Mexico Department of Health
- Santa Fe, New Mexico
- Roland C. Lamb
- Director, Methadone Clinic
- Parkside Human Services and Associates
- Philadelphia, Pennsylvania
- Beny J. Primm, M.D.
- Executive Director
- Addiction Research and Treatment Corporation
- Brooklyn, New York
- Richard B. Resnick, M.D.
- Clinical Associate Professor, Department of
- Psychiatry
- New York University School of Medicine
- New York, New York
- Marianne L. Scheck, R.N., B.S., C.A.D.C.
- Mental Health Specialist I
- Family Support Team, Children's Services
- Division
- Marion County Drug Treatment Program
- Salem, Oregon
- Harold C. Urschel III, M.D., M.B.A.
- President and CEO
- The Urschel Enterprise Group
- Dallas, Texas
- Janicemarie K. Vinicky, Ph.D.
- Chairperson, Department of Bioethics
- Washington Hospital Center
- Washington, D.C.