# What Is a TIP?

CSAT Treatment Improvement Protocols (TIPs) are prepared by the Quality Assurance and Evaluation Branch to facilitate the transfer of state-of-the-art protocols and guidelines for the treatment of alcohol and other drug (AOD) abuse from acknowledged clinical, research, and administrative experts to the Nation's AOD abuse treatment resources.

The dissemination of a TIP is the last step in a process that begins with the recommendation of an AOD abuse problem area for consideration by a panel of experts. These include clinicians, researchers, and program managers, as well as professionals in such related fields as social services or criminal justice.

Once a topic has been selected, CSAT creates a Federal resource panel, with members from pertinent Federal agencies and national organizations, to review the state of the art in treatment and program management in the area selected. Recommendations from this Federal panel are then communicated to the members of a second group, which consists of non-Federal experts who are intimately familiar with the topic. This group, known as a non-Federal consensus panel, meets in Washington for 5 days, makes recommendations, defines protocols, and arrives at agreement on protocols. Its members represent AOD abuse treatment programs, hospitals, community health centers, counseling programs, criminal justice and child welfare agencies, and private practitioners. A Chair (or Co-Chairs) for the panel is charged with responsibility of ensuring that the resulting protocol reflects true group consensus.

The next step is a review of the proposed guidelines and protocol by a third group whose members serve as expert field reviewers. Once their recommendations and responses have been reviewed, the Chair approves the document for publication. The result is a TIP reflecting the actual state of the art of AOD abuse treatment in public and private programs recognized for their provision of high quality and innovative treatment.

This TIP, titled LAAM in the Treatment of Opiate Addiction, presents current knowledge about the use of levo-alpha-acetyl-methadol (LAAM), an opioid agonist medication approved for use in 1993. LAAM suppresses opiate withdrawal symptoms for more than 72 hours, and it can be administered no more frequently than every other day. Thus, daily visits to the program clinic are not required for LAAM-maintained patients, as are visits for patients on methadone. In addition to the difference in dosing schedule, no take-home doses of LAAM are permitted under Federal regulations, and women of child-bearing potential must be tested monthly for pregnancy.

The introduction of LAAM into the current treatment system will require programs to educate staff and patients about the use of LAAM. This TIP describes the medication itself, its mode of action, possible side effects, and interactions with other medications. A separate chapter on clinical use of LAAM presents guidelines for selecting patients who may benefit from LAAM and starting and maintaining them on the medication. A chapter on treatment planning addresses issues that may arise for counselors and patients, such as structuring free time and creating incentives for treatment progress. Issues for program managers and administrators, including staff education and costs of LAAM, are discussed in another chapter. A chapter on regulatory and ethical issues is included. As LAAM is introduced, programs will be a source of important data about its use, and the TIP presents suggestions for research in several areas.

This TIP represents another step by CSAT toward its goal of bringing national leadership to bear in the effort to improve AOD abuse treatment.

Other TIPS may by ordered by contacting the National Clearinghouse for Alcohol and Drug Information (NCADI), (800) 729-6686 or (301) 468-2600; TDD (for hearing impaired), (800) 487-4889.