# Chapter 6 - Regulatory and Ethical Issues

This chapter provides an overview of the Federal regulations governing the use of levo-alpha-acetyl-methadol (LAAM), which are a subset of the regulations for all opioid substitution therapy programs (see Exhibit 6-1). The chapter also presents suggestions for States that desire to develop their own LAAM regulations. How the use of LAAM might affect other systems, such as the public health system, is described. Ethical issues involved in introducing LAAM treatment are discussed.

Exhibit 6.1 Federal Narcotic Treatment Regulations

Federal Narcotic Treatment Regulations: Language Specifically Relating to Use of LAAM
21 C.F.R. Part 291 Section 291.505 (1993)
(d)(1)(iii)(B)(6)
Patients who are or become pregnant should not be started or continued on LAAM, except by the written orders of a physician who determines this to be the best choice of therapy for that patient. Clinics providing treatment with LAAM must advise all patients of childbearing potential of the risks of LAAM and make a medical evaluation available to all patients who become pregnant while taking the drug. An initial pregnancy test shall be performed for each prospective female patient of childbearing potential before admission to LAAM comprehensive maintenance treatment and monthly pregnancy tests performed thereafter on such female patients in LAAM comprehensive maintenance treatment. Analysis of such tests shall be performed in a laboratory approved under the Clinical Laboratory Improvement Amendments of 1988 or in a laboratory certified by a State or private accrediting body approved by the Health Care Financing Administration.
(d)(1)(iv)(B)
A person under 18 years of age shall not be admitted to LAAM maintenance treatment.
(k)(1) LAAM
(i) Dosage and responsibility for administration. After a patient's tolerance to LAAM is established, LAAM shall be administered no more frequently than every other day. Dosage of LAAM shall be individualized at doses, frequencies, and under conditions of usage described in approved labeling and as follows:
(A) New patients. The persons responsible for the program shall ensure that the initial dose of LAAM to a patient whose tolerance for the drug is unknown does not exceed 40 milligrams.
(B) Stabilized methadone maintenance patient. The persons responsible for the program shall ensure that the initial dose of LAAM for a previously stabilized methadone maintenance patient is less than or equal to 1.3 times the patient's daily methadone dose, not to exceed 120 milligrams.
(C) A licensed physician shall assume responsibility for the amount of the narcotic drug administered or dispensed and shall record, date, and sign or countersign in each patient's record each change in dosage schedule.
(D) The administering licensed physician shall ensure that a single dose of LAAM greater than 140 milligrams is justified in the patient's record.
(ii) Dosage form. LAAM may be administered in oral form when used in a maintenance treatment program. Hospitalized patients under care for a medical or surgical condition are permitted to receive LAAM in oral form when the attending physician judges it advisable. Although syrup concentrate or other formulations may be distributed to the program, all oral medication is required to be administered in a liquid formulation. Clinics that administer both LAAM and methadone shall take appropriate measures, including contrasting color and taste, to ensure that dosage forms of LAAM and methadone are easily distinguished.
(iii ) Take-home medication. Take-home doses of LAAM are not permitted. A patient who is eligible for one or more take-home doses of methadone under paragraph (d)(6) of this section and who is unable to conform to the applicable mandatory LAAM dosing schedule because of exceptional circumstances such as illness, personal or family crises, travel, or other hardship, or official State holidays, may be temporarily transferred to methadone. Take-home doses of methadone for a patient eligible for a planned temporary discontinuation of treatment with LAAM shall be individualized at doses, frequencies, and under conditions of usage described in the approved labeling and the applicable provisions for take-home methadone medication under paragraph (d)(6) of this section. The maximum number of take-home doses of methadone shall be determined in accordance with the provisions of 21 C.F.R. Part 291 Section 291.505(d)(6)(v) and (d)(6)(vi) (1993).

The Center for Substance Abuse Treatment (CSAT) has developed two publications that provide information about the regulation of opioid substitution therapy. The first, State Methadone Treatment Guidelines, is another Treatment Improvement Protocol (TIP) in this series that provides guidelines for States and programs to provide high-quality care in compliance with the regulations. The second publication Approval and Monitoring of Narcotic Treatment Programs: A Guide on the Roles of Federal and State Agencies is part of CSAT's Technical Assistance Publications (TAP) series. To those seeking to establish an opioid substitution therapy program, the latter offers a step-by-step overview of what to expect from Federal and State agencies during the program approval and monitoring process. Sample application forms are provided. Both publications are available free of charge from the National Clearinghouse for Alcohol and Drug Information.

## Approval of Treatment Programs to Dispense LAAM

### Approval Process

Opioid substitution therapy programs seeking to become approved to administer LAAM must apply to the Food and Drug Administration (FDA) and to the State in which they intend to operate. Federal programs, such as those operated by the Department of Veterans Affairs, may use LAAM treatment even if the State in which they are located has not yet approved LAAM for use by treatment programs.

Opioid substitution therapy programs seeking to become approved to administer LAAM must apply to the Food and Drug Administration and to the State in which they intend to operate.

Typically, an application must also be made to the Drug Enforcement Administration (DEA) and notice given to the single State agencies (SSAs). At present, only programs that are approved to use methadone are eligible for approval to administer LAAM.

Some States require programs to obtain approval, some certification, and some licensure. Some States are still in the process of obtaining the necessary approvals or amending regulations to permit use of LAAM. (All States have their own controlled substances laws and must reschedule LAAM from a Schedule I to a Schedule II drug in order to allow clinics access to it [see below].) The SSAs can advise treatment providers about whether LAAM is currently available in their States and about the steps to follow to add LAAM therapy to their treatment regimens. Providers should contact their State methadone authority. It and the SSA are the best sources of information regarding local licensing and regulatory requirements. The SSA is responsible for ensuring that use of LAAM is approved, that all licensing and approval requirements are met, and that programs are in compliance with the laws of the State.

The addition of LAAM therapy to a clinic's treatment options will necessitate an expansion of the program's philosophy and mission statement. As a result, program manuals, consent forms, and treatment approaches may need revision. Forms related to release of information may also need revision. In addition, programs may need to rewrite protocols for the dispensing and storage of drugs to meet DEA requirements. Many of these revisions can simply follow the method used by the Federal Government in revising the Federal Narcotic Treatment Regulations. The word "methadone" was struck out wherever it occurred and the term "narcotic drugs," a more inclusive term for the class of medications that includes methadone and LAAM, was substituted. This method of revision obviates the need to revise the basic regulations each time a new medication is introduced; language pertinent to the new medication may simply be added (see Exhibit 6-1).

All opioid substitution therapy programs are subject to a thorough inspection process related to the safety and security of inventory and storage control for medications. Some States also require an onsite review focusing on program protocols, qualifications of clinical staff, and patient records.

Regulatory monitoring, whether by the State or another oversight body, focuses on patient outcomes as well as compliance with recordkeeping procedures. Members of inspection teams may wish to conduct interviews with patients and staff to better evaluate patient outcomes. Individuals with backgrounds in treatment should have a role in the design and implementation of regulatory monitoring procedures. All regulatory monitoring should be followed by technical assistance in areas of identified need. Punitive approaches are counterproductive and may contribute to poor patient retention in programs.

During the Labelling Assessment Study of LAAM, the DEA insisted that programs keep methadone and LAAM medications separate; that is, each medication should have a distinct dispensing vehicle and be stored separately (although not necessarily in separate safes). Patient records should be coded so that records for patients receiving LAAM can be easily identified. Programs must establish methods of distinguishing clearly between methadone and LAAM patient records or files, particularly in dispensing and inventory procedures. This requirement should be continued in the interest of patient safety and adequate accountability of medications, especially in States where local regulations do not differentiate between LAAM and methadone.

The inspecting agency (that is, DEA or the local drug control agency) should clarify its requirements related to the separation of methadone and LAAM in terms of inventory control, storage, dispensing, and administration to ensure safety, efficacy, and ease of operation.

Patient records should be coded so that records for patients receiving LAAM can be easily identified. Programs must establish methods of distinguishing clearly between methadone and LAAM patient records or files, particularly in the dispensing and inventory procedures.

### The Future of LAAM Regulation

FDA is moving into an era of opioid substitution therapy as a general, expanded concept of therapy, as opposed to a more narrow modality named after a specific medication--methadone. The introduction of LAAM therapy for narcotic addiction treatment is likely to pave the way for the introduction of other medications that are opioid substitutes and for adjunct treatment medications.

States that prefer to write their own regulations for LAAM, as well as those that have regulations related to methadone and wish to add LAAM to them, should be encouraged to do so in such a way that the regulations need not be rewritten each time a new opioid addiction medication using Schedule I or II compounds is introduced. This process can be accomplished by using generic terms such as opioid substitution therapy, narcotic addiction treatment (the Federal term), narcotic treatment services, or narcotic addiction therapies, rather than LAAM therapy. This language will facilitate future revision of the regulations.

States should consider an expedited regulatory mechanism for scheduling new medications, thereby encouraging treatment programs to utilize the latest developments in pharmacological therapy, as long as the technology and indications are not radically different (such as an antagonist medication rather than an agonist medication). States may want to consider how regulations must vary if a new medication were classified as a Schedule VI drug rather than a Schedule II drug, allowing greater flexibility and use by physicians in office practice.

All States have their own controlled substances laws and must reschedule LAAM from a Schedule I to a Schedule II drug in order to allow clinics access to it. The mechanism for rescheduling varies by State. States may want to explore the use of an automatic scheduling process that would mirror (or replicate) Federal scheduling of new medications for use in treatment. The alternative can be a long process requiring the approval of several State agencies before rescheduling takes place. (As of this writing, LAAM has still not been rescheduled in some States.) Such processes create barriers to programs that want to offer the latest advances in pharmacological therapy.

States are strongly encouraged to write regulations to incorporate "sunsetting"--that is, a mechanism requiring that regulations be reviewed and updated within a specified period of time (for example, 3 years, as in Texas). This review would allow the regulations to reflect advances in the field (new medications and new treatment modalities) in a timely manner.

States are strongly encouraged to write regulations to incorporate "sunsetting"--that is, a mechanism requiring that regulations be reviewed and updated within a specified period of time (for example, every 3 years).

Regulations should emphasize that medications and services must be delivered together, in a complementary fashion, for any treatment medication. Programs using LAAM therapy must have the capability to administer methadone as needed in order to adequately address patients' needs, ensure their safety, and resolve problems of individual patients. Considerations must include necessary patient travel, vacations, program holidays, disasters, inclement weather, and other logistical issues. Serious consideration should be given to modifying the regulations to allow take-home doses of LAAM in cases in which there is a clinical need. (See Chapter 3 for suggested ways of handling interruptions in treatment.)

Training requirements should be included in State regulations, which should specify a minimum amount of staff training required per year in order to be licensed to operate. Minimum annual training should include some basic coverage of pharmacology. For example, 24 hours of annual training might include 3 hours of psychopharmacology and an additional 12 hours related to opiate addiction treatment. Because data about LAAM therapy is still accumulating, training should be constantly upgraded.

### Role of the States

Any State agencies that regulate dispensing and pharmacy would normally be involved in the program approval process. States that regulate dosage and other clinical matters should ensure that their regulations are consistent with the new clinical guidelines for methadone maintenance; they should not use the same criteria for LAAM as for methadone. Regulations should avoid drug-specific requirements (such as specifying dose levels) and should be based on treatment efficacy rather than solely on community, philosophical, or ideological concerns.

### Role of Treatment Programs

States that develop a certification or licensure process and regulations should involve providers (and consumers) within the State in the development of certification protocols and new regulations. When appropriate, States should contact programs in other States that have had experience with LAAM (through clinical trials) and their SSAs, as well as the National Institute on Drug Abuse (NIDA) and the Center for Substance Abuse Treatment, when developing or revising regulations.

Treatment programs should serve as the primary sources of data on therapeutic protocols, advances, and the need for regulations. Programs should be proactive and work cooperatively with States by investing the time and energy in the regulatory process to develop useful and practical regulations and encourage regulatory changes. With the current restrictions on LAAM, such as lack of take-home doses and restrictions on use in pregnant women, it is not possible to use the new medication to its greatest potential for patients' needs. Clinical personnel should be proactive in focusing on optimal patient needs and working toward regulations that will better meet those needs.

### Treatment Standards

SSAs should evaluate opioid substitution therapy programs that incorporate LAAM treatment by using a combination of outcomes variables and process variables. Outcomes evaluations in alcohol and other drug (AOD) abuse treatment programs have thus far focused on discharged patients, an approach that is highly inadequate for measuring the success of maintenance therapies. It is hoped that the introduction of LAAM therapy will move the evaluation process toward an effective and clinically relevant one in which outcomes variables are based on patient achievements (and quality-of-life improvements as a result of the treatment process), not on the numbers of patients "successfully" discharged (McLellan and Durell, submitted for publication).

The expansion of narcotic addiction treatment to include LAAM therapy puts programs in a position to improve outcomes evaluation. Outcomes variables should be defined in a way that measures progress rather than failure. A program should evaluate treatment outcomes with an instrument that is predictable, reliable, valid, and targeted to the goals of the program--and communicate the results of that process to the State, in order to add to the information base from which regulatory change derives. (See Chapter 5 for a discussion of outcomes measures.)

### Integration of AOD Treatment With Other Health Care Services

Patients who need opioid substitution therapy should be assessed by a clinician who is familiar with the treatment alternatives but who does not have a stake in which modality is chosen. Thus, some form of centralized intake may be required. Such a system must use a standardized assessment procedure for patients, who may have a variety of problems. The availability of treatment slots must be known. Assessment staff must understand the types of treatment offered and the populations served, as well as the characteristics of both patients and programs that will facilitate optimal matching of patients to appropriate treatment modalities. States that have target cities programs should be further along in the development of centralized intake and standardized assessment systems.

Treatment programs serve as the primary sources of data on therapeutic protocols, advances, and the need for regulations. Clinical personnel should be proactive in working toward regulations that will better meet patient needs.

States should ensure that several systems and agencies work together to integrate services. These include the substance abuse treatment, mental health, public health, criminal justice, and primary medical care delivery systems. This approach will assist programs in the transition to managed care. Thus, it behooves States and programs to integrate the services of all systems. If they do not, they run the risk of being subject to the decisions of an outside agent that may not integrate services in a quality-focused manner.

## Use of LAAM: Effects on Other Systems

The introduction of LAAM treatment has implications for other areas of the substance abuse treatment system, not just opiate addiction treatment programs. The introduction of LAAM treatment will have effects on other systems and organizations, as discussed below.

### Public Health Services

It has been suggested that, like methadone maintenance, LAAM could stretch the public health treatment dollar by reducing the spread of sexually transmitted diseases and human immunodeficiency virus (HIV) (through needle sharing) and integrating public health and substance abuse treatments. The anticipated reduction in waiting lists due to the introduction of LAAM treatment may also eventually result in decreases in HIV and acquired immunodeficiency syndrome (AIDS) and the associated risk and incidence of tuberculosis. Success with either methadone or LAAM maintenance results in a stabilized patient in treatment, and continuing treatment has been shown to reduce high-risk behavior, improve overall health, and reduce health care costs related to other medical complications. These are important public health concerns.

HIV imposes huge costs in health and human terms. Mainstream medicine--including managed care companies, health maintenance organizations, and other health care providers--may be willing to accept LAAM because it is new and may be implemented in a more innovative way than the current methadone maintenance treatment programs. It is also being introduced at a time when harm reduction is an important public health consideration.

### Criminal Justice System

Regulatory restrictions and the past hostility of prison administrators to opioid substitution therapy make it unlikely that many prisons will provide this treatment, but prisons that have licenses to dispense methadone should expand their capabilities to include LAAM treatment. In fact, LAAM should be easier for prison health authorities to provide because of the reduced dosing schedule.

Until LAAM is widely used, prison staff may not know how to handle patients receiving LAAM. Criminal justice system staff (including judges) should receive the same type of education that is provided to health care providers to familiarize them with the pharmacology and use of LAAM.

States should write regulations that encourage methadone or LAAM maintenance of patients whose expected period of incarceration is short (less than 3 months).

### Social Service Organizations

Fewer clinic visits will give LAAM-maintained patients a more flexible schedule, allowing them to better avail themselves of the services of social service organizations. Such organizations include agencies that provide legal, vocational, educational, and family social services, such as job training programs.

### Insurance, Reimbursement, and Funding Organizations

Insurers frequently set caps on the number of visits to treatment programs of any kind. They often do not distinguish ongoing maintenance treatment as a separate modality that requires frequent visits. Treatment programs and others in the substance abuse treatment system should work to ensure that funding agencies, payers, and insurance companies receive education about the cost-effectiveness of opioid substitution therapy, including LAAM treatment. This will help insurers understand that it is not appropriate to arbitrarily cap the number of visits.

Medical costs associated with untreated opiate addiction can be high. Patients who enter opioid substitution therapy usually suffer from years of neglected health and welfare. Thus, in the first year of treatment, costs may be greater than in later years. However, once the patient enters treatment, the program can provide some assurance that the patient will receive appropriate and cost-effective services. In particular, programs can help patients access primary care rather than hospital and emergency room care, access which will reduce costs. Because the use of LAAM offsets other medical costs, insurers should cover LAAM therapy and be willing to reimburse costs of required pregnancy tests. Insurers should view health problems in substance-abusing patients in the same way as those in other populations.

Because the use of LAAM offsets other medical costs, insurers should cover LAAM therapy. Treatment programs and others in the substance abuse treatment system should work to ensure that funding agencies, payers, and insurance companies receive education about the cost-effectiveness of LAAM treatment.

## Ethical Issues in the Administration of LAAM

The decision to medicate with LAAM or methadone should be made with a focus on the patient rather than on financial considerations or programmatic convenience. Programs with a patient mix that includes both publicly funded and private-pay patients should ensure that the source of reimbursement does not dictate the medication or other treatment services delivered. Programs must evaluate their treatment decisions in light of good ethical practice and not succumb to the temptation to overload their program staff with more patients than can be treated in a comprehensive, patient-focused manner.

### Informed Consent and Confidentiality

Informed consent is an ongoing process of interaction between staff and patients about treatment decisions. Its goal is to lead to informed choice. Patients must understand the nature and purpose of the treatment; its potential risks, side effects, and benefits; any interactions with other drugs or treatments; and alternative therapies.

Programs are encouraged to develop an educational process that includes the following elements, documented in the patient record with a signature:

1. Patient hears the information (adequate disclosure).
2. Patient understands the information (assessment that disclosure was comprehended).
3. Staff assesses patient voluntariness (voluntariness is absent when a patient makes a choice solely out of desperation or other emotional reactions) and reasons for making the choice (capacity for decisionmaking). Program staff are then obligated to make the best choice based on this assessment.

The confidentiality issues attending the administration of LAAM are identical to those surrounding all other forms of AOD abuse treatment. Several TIPs in this series have separate chapters that present detailed guidelines for providing substance abuse treatment in compliance with the Federal confidentiality regulations. For example, the reader is referred to Chapter 5 of the TIP Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases. Issues addressed include the proper use of consent forms and communicating with other agencies. CSAT has also prepared a separate document Confidentiality of Patient Records for Alcohol and Other Drug Treatment, as part of its Technical Assistance Publication (TAP) series. The TAP contains sample patient consent forms and other forms for programs to use in releasing information to other agencies.

### Noncompliance and Termination

In the process of providing patient education and obtaining informed consent, women should be told specifically that if they become pregnant while receiving LAAM, the physician will switch them to methadone. Staff should ensure that a patient understands this information. After the pregnancy, patients may be transferred back to LAAM.

Providing information about the consequences of noncompliance should be part of the informed consent process. The criteria for noncompliance should be clear to patients and should not differ for LAAM and methadone patients. Programs should avoid terminating patients from treatment for continued substance abuse problems. Rather, programs should seek improved or alternative treatment plans or methods that may better meet patients' needs.

Treatment is not punishment, and patients should not be changed involuntarily from one medication to another nor should the treatment be changed in any way that they might perceive as a punishment. Clinic staff should ensure that a patient understands the reason for any medication change.

### Advertising

It has been reported that some programs have engaged in unethical advertising practices. For example, some programs have told patients that they would receive extra take-home medication if they brought a new patient into treatment. Some programs have advertised that they give higher doses and more take-home doses than "competing" programs in the area.

Treatment is not punishment, and patients should not be changed involuntarily from one medication to another nor should the treatment be changed in any way that they might perceive as a punishment. Clinic staff should ensure that a patient understands the reason for any medication change.

Advertising by opioid substitution therapy programs should be approached with great care and sensitivity--especially advertising in print or electronic media. A program may seek to "market" its services in places where referrals are likely to be found, such as emergency rooms, detoxification centers, police stations and other criminal justice agencies, and health and human service agencies. Churches and other groups that help community members in distress can also be approached. In certain geographic regions, it may be valuable to recommend that clinics form associations for self-regulation of issues such as advertising.

### Quality of Care

Some patients are not ready to engage fully in treatment. The question of whether it is appropriate to use LAAM while delivering minimal clinical services until the patient engages in treatment should be examined carefully. "Minimal" services usually involve an initial assessment of severity of substance abuse, which allows clinicians to determine the level of care a patient will receive when he or she enters treatment. In some situations, case management is provided for patients whose conditions require immediate and ongoing attention. In addition, some further contact is necessary for urinalyses to ensure that the patient is not using other substances. This level of services may be appropriate for patients who are unable to engage in treatment for psychosocial or medical reasons. Minimum treatment should include TB testing and HIV prevention education, which is required under Federal block grant regulations.