# Chapter 3 - Clinical Application of LAAM Therapy

Both clinical and practical considerations are involved in deciding which patients are appropriate for levo-alpha-acetyl-methadol (LAAM) treatment. Patients can be inducted directly onto LAAM or can be transferred from methadone to LAAM. This chapter provides guidelines for selecting patients for LAAM treatment and stabilizing them on the medicine.

Dose scheduling is key to successfully maintaining stabilized patients on LAAM. Two factors specific to LAAM--its long-acting nature and the fact that regulations do not permit take-home doses--make dose scheduling more complicated than with methadone. Dosing can be scheduled every other day, if the clinic is open on Sunday. Three-times-weekly dosing (two 48-hour doses and a 72-hour dose) can also be used. Programs should have procedures for addressing Monday holidays and other planned and unplanned interruptions of regular LAAM dosing. For planned absences, supplemental doses of methadone may be given to patients who are allowed take-home methadone. The chapter describes approaches to addressing dosing and scheduling issues.

## Selection of Patients

Research to date provides no clear-cut indicators that determine which individuals will benefit most from LAAM therapy. Until more ic effects of drugs used to supplement LAAM.

People who have been on methadone maintenance a long time but still report for medication six or seven times a week because of State or local policy on take-home methadone. These patients in particular may appreciate that fewer clinic visits are required by LAAM therapy.

Chronic relapsers, including those who have been on methadone for a long time but who remain uncommitted to the goals of treatment. Most chronically noncompliant patients do not appear to benefit from daily visits to the clinic, and many visit the clinic only because they are not allowed take-home medication. Many such patients disrupt clinic routines and, over a long period of time, have exhausted staff attempts to engage them in treatment. Members of the consensus panel felt that use of LAAM therapy with some of these patients would have the advantage of reducing disruptive clinic visits and making it easier for staff to provide care to others. Panel members understood that recommending LAAM therapy for this group was controversial; patients in this group should be carefully selected. LAAM therapy should never be used as a punishment.

Daily clinic attendance by the three groups may be reduced with LAAM therapy. Patients who have been stable on methadone maintenance for a period of years probably receive take-home doses and would experience no reduction in visits when transferring to LAAM. However, according to Federal regulations, a patient must be in opioid substitution therapy for 2 years before he or she is eligible for enough take-home methadone to allow only two clinic visits per week. Thus, patients in the first 2 years of methadone treatment may benefit from LAAM therapy. (After 3 years of treatment, the Food and Drug Administration [FDA] regulations permit a 6-day supply of methadone for patients meeting certain conditions, thus allowing them once-a-week clinic visits. State regulations vary.)

### Practical Considerations and Clinical Factors

In considering candidates for LAAM therapy, common sense and practical considerations should prevail. Patients with mobility problems may find LAAM treatment an attractive alternative, because fewer visits mean less frequent travel requirements. Similarly, patients in inner cities who lack transportation, those in rural areas who must drive long distances to the clinic, and those with scheduling conflicts may also find LAAM therapy a desirable alternative. Patients (such as those with dementia) for whom age or illness makes managing take-home medication difficult may also derive some benefits. Patients in States where take-home doses of methadone are not allowed or are in practice severely restricted may also benefit from the introduction of LAAM treatment. Patients in these States could have more opportunities to engage in other productive life experiences (such as employment and job training) under LAAM's reduced dosing schedule. However, treatment choices based on these considerations alone should be avoided.

Among the appropriate target population for LAAM therapy are three main groups:

- People entering treatment, either from the street or in their first 2 years of methadone maintenance
- People who have been on methadone maintenance a long time but still report for medication six times a week because of State or local policies on take-home methadone
- Chronic relapsers, including those who have been on methadone for a long time but who remain uncommitted to the goals of treatment.

Although use of LAAM raises these and other practical issues, the decision to use LAAM should be governed by clinical factors, including the patient's desire and the belief that LAAM offers the optimal means for achieving the goals of maintenance treatment. LAAM therapy should not be selected because a clinic is trying to achieve formulas or meet quotas of LAAM patients.

The decision to use LAAM should be framed from the patient's perspective. Staff may find it useful to present the available range of opiate addiction treatment alternatives to a patient in a manner similar to that used in family planning counseling. Such conversations may extend over more than one counseling session to allow the patient to assimilate the information. (However, treatment with methadone can begin right away.) To help the patient make an informed choice, program staff should present the advantages and disadvantages of the treatment options and give the patient the opportunity to ask questions and to participate in the treatment selection.

Every treatment choice has particular advantages and disadvantages. For example, some patients may need daily clinic visits as a component of their treatment program; less frequent visits may help other patients establish a more normal routine that is not as structured around clinic visits as is necessary when receiving methadone. For the latter group, use of LAAM offers distinct benefits. Although use of LAAM eliminates the need for daily clinic visits, it also eliminates the option of take-home medication. For some patients, the loss of take-home medication as an indicator of treatment progress may present problems. For others, take-home medication may not be achievable, and LAAM will provide an alternative method of reducing the frequency of clinic visits.

To help the patient make an informed choice about LAAM treatment, program staff must present the advantages and disadvantages of all treatment options and give the patient the opportunity to ask questions and to participate in the treatment selection.

### Intake and Assessment

The components of the psychosocial assessment for LAAM therapy are consistent with those for methadone treatment. Guidelines for assessment of patients are presented in two other TIPs State Methadone Treatment Guidelines and Matching Treatment to Patient Needs in Opioid Substitution Therapy.

Patients who are being considered for LAAM therapy can be divided into two major groups: those who are already in an opioid substitution therapy program and those who are not. The latter category includes patients who are not currently dependent on opioids, for example, those recently released from incarceration or chronic care institutions who meet FDA criteria for admission without proof of current physical dependence, 21 C.F.R. Part 291 Section 291.505(d)(1)(iii)(A) (1993).

Patients who are appropriate candidates should be offered other treatment options if they are not able to tolerate LAAM therapy.

### Criteria for Determining Eligibility: Federal Requirements

Federal eligibility requirements for methadone maintenance treatment stipulate that people with a minimum 1-year history of opiate addiction and who have current physical dependence may enter maintenance treatment. The minimum age requirement is 18 years; persons between 16 and 18 years of age may enter methadone treatment under certain conditions. There is no upper age limit on entry to care. Pregnant women may be accepted for methadone treatment and, with special medical justification, may be admitted under modified criteria. Persons with major medical conditions are eligible for treatment, as are polydrug abusers. Details on methadone eligibility guidelines are found in the TIP State Methadone Treatment Guidelines.

Federal eligibility requirements for LAAM treatment are identical to those for methadone, with the following three major exceptions. LAAM is not approved for use by

- Pregnant women
- Nursing mothers
- Persons under the age of 18 years.

### Pregnant Women and Nursing Mothers

LAAM is classified by FDA as a category C drug, that is, a drug for which "animal studies show adverse effects on fetus but no adequate studies in humans; benefits from drug during pregnancy may outweigh risks, OR no animal reproduction studies and no adequate human studies," 21 C.F.R. Part 291 Section 201.57(f)(6)(i)(c) (1994). Federal guidelines state that because LAAM is not approved for use during pregnancy or while nursing, "patients who are or become pregnant cannot be started or continue on LAAM, except by written order of a physician who determines this to be the best choice of therapy for the patient" (Food and Drug Administration, 1993).

Any predictions of the effects of LAAM on pregnant or nursing women and the fetus at this time are speculation. For example, because of its slower action, LAAM may produce fewer withdrawal effects on the fetus; on the other hand, LAAM metabolites might accumulate in utero. Like other mu agonist opioids, LAAM may cause respiratory depression in the fetus and other perinatal complications during delivery. It is not known whether LAAM is excreted in breast milk.

Many other drugs have been approved for use during pregnancy, even though their effects on the fetus and newborn are unknown. When there is no treatment alternative, the physician must decide whether to treat a pregnant woman. However, an adequate and proven substitute for LAAM exists - methadone. Until research has demonstrated the safety of LAAM in pregnant women and nursing mothers, it is recommended that patients who become pregnant or are nursing be transferred to methadone. Exceptions to this practice are likely to be extremely rare. The sole circumstance under which LAAM might be acceptable is when the only alternative is a return to heroin use.

Counseling concerning the potential risks of LAAM during pregnancy and nursing should be provided to both male and female patients. Women should receive written and oral information about the potential risks of taking LAAM during pregnancy, and this information should be periodically reinforced.

Regular pregnancy testing should be available in all substance abuse treatment programs; women with substance abuse problems are a high-risk population in terms of receiving poor prenatal care. Testing for sexually transmitted diseases (STDs) as well as for human immunodeficiency virus (HIV) should also be made routinely available to these patients. These tests should be offered, along with onsite access to or referral for family planning services and counseling. Regular pregnancy testing for patients receiving LAAM may be more easily integrated into the program if it is presented as part of an overall women's health initiative.

Mandatory pregnancy testing should be presented to women as a positive treatment benefit. Testing has many benefits, provided that positive results are followed up by good prenatal care and appropriate support. Open discussion of issues related to reproductive health can strengthen the patient-staff relationship, which may in turn enhance treatment progress.

Regular pregnancy testing should be available in all substance abuse treatment programs, because women with substance abuse problems are a high-risk population in terms of receiving poor prenatal care.

### Persons Under 18 Years of Age

Federal regulations prohibit any person under 18 years of age from entering LAAM maintenance treatment because there are no adequate studies to support its use among persons of this age. Some people question whether arbitrary limits such as these, in the absence of clinical data, are counterproductive. Studies are needed to provide a scientific basis for the exclusion of any group of patients from LAAM therapy.

### Medical and Other Considerations

Use of LAAM has been studied in several subgroups of patients, and results are summarized below.

Persons with comorbid medical conditions. Persons with elevated liver enzyme levels should not automatically be ruled out as candidates for LAAM therapy. LAAM treatment is generally not recommended for persons with hepatic failure. (For further information on the effects of liver disease, see Chapter 1.)

Persons with comorbid psychiatric conditions. A person should not be excluded as a candidate for LAAM therapy solely on the basis of psychiatric symptoms. There is generally no reason to believe that the treatment of patients with coexisting psychiatric illness should be different with LAAM than with methadone. Psychiatric symptoms should be evaluated and treated, and decisions about maintenance therapy made in conjunction with the provision of such treatment.

Patients who do not succeed on one of the two opioid agonists available for treatment (methadone and LAAM) should be tried on the other if there are no contraindications (such as pregnancy). Anecdotal reports indicate that some patients may benefit from LAAM therapy because they experience a more level effect than with methadone; some patients receiving methadone report an "up-and-down" cycle.

Patients with previous experience of side effects from LAAM. Persons who have experienced side effects from the drug in the past are generally inappropriate candidates for LAAM treatment.

Psychosocial considerations. Some patients have avoided opioid substitution therapy because of the stigma associated with methadone. The question of whether they are appropriate candidates for LAAM treatment cannot be answered with a simple "yes" or "no." The counselor's first task is to ensure that the patient has been given the information necessary to make an informed choice. Sensitive counseling can alleviate anxiety and facilitate rational decisionmaking.

## Induction Onto LAAM

### Steady-State Pharmacology

An understanding of the basics of steady-state pharmacology is essential for the safe induction of patients onto methadone or LAAM therapy. When a drug is given at regular intervals before the previous dose is eliminated from the body, there is an accumulation of the drug in the body until a steady state is reached. The term steady state refers to a condition in which the amount of a drug entering the body is equal to the amount being excreted, which allows a relatively constant serum (blood) level of the drug. For any drug, the time needed to reach steady state is a function of its elimination half-life. The half-life is the amount of time required for the body to eliminate half of a given dose of a drug.

It is important for physicians, staff, and patients to understand that the second dose is added to the portion of the previous dose that is still in the body, resulting in higher blood levels with no increase in dose. This continues until steady state is achieved.

The terms steady state and stabilization should not be confused. Steady state has been achieved when the dose of LAAM administered lasts for the intended length of time. In contrast, a patient is stable when he or she no longer exhibits drug-seeking behavior or craving. At this point, both the patient and supportive services staff can begin to focus on medical, lifestyle, and psychosocial issues, and on other treatment.

Steady state is based on multiples of the elimination half-life. Approximately four to five half-life times are needed to establish the steady state. For example, methadone has a half-life of 1 to 1.5 days (24 to 36 hours); therefore, the steady state for methadone--that is, the time at which a relatively constant dose level is present in the body -- is achieved in 5 to 8 days in most patients (see Exhibit 3-1).

Exhibit 3.1 Half-life and Steady-State Times of Methadone and LAAM

Medication | Half- life | Time to Steady State
Methadone | 1 to 1.5 days | 5 to 7.5 days
LAAM | 2.6 days | 10.4 to 13 days
Nor-LAAM | 2.0 days | 8 to 10 days
Dinor-LAAM | 4.0 days | 16 to 20 days

It takes longer to reach a steady state of LAAM in the body because the parent drug and each metabolite (nor-LAAM and dinor-LAAM) have a longer half-life than methadone. The half-life of LAAM (parent drug) is 2.6 days, that of nor-LAAM, 2 days, and that of dinor-LAAM, 4 days. Because of their different half-lives, each requires a different time to achieve steady state; the length of time is calculated by multiplying the half-life by a factor of four to five (Exhibit 3-1). Thus, although the first dose of LAAM, if it is adequate, will eliminate withdrawal symptoms, and such symptoms should be well controlled by the second or third dose, the pharmacological steady state is not realized for 16 to 20 days.

### Method of Induction Onto LAAM Treatment

Patients selected for LAAM therapy can be inducted onto the medication either by direct induction onto LAAM or by a standard methadone induction followed by a change to LAAM once the patient is stabilized on a methadone dose. The program's clinical staff, in consultation with the patient and family (with patient consent), can choose between these two options. With either method of induction, LAAM offers clinicians a choice in how to carry out induction--a choice that can affect outcomes. No choice should be irreversible, however, and clinicians should be open to trying another induction method if the initial decision does not appear to be effective. Although the current literature on LAAM therapy provides no clear indications to direct clinicians and practitioners in this decision, the guidelines that follow may be helpful.

### Initial Methadone Stabilization Versus Direct Induction

Induction onto a stabilizing regimen of methadone before LAAM treatment is begun affords clinicians the ability to observe the patient on a daily basis. Such an approach can be helpful if the patient is dependent on other drugs, including alcohol. Patients who are initially inducted onto methadone may expect a more rapid onset of effect, which may be an advantage in some cases. Another potential advantage of methadone induction may be the clinician's familiarity with methadone's action and side effects.

Direct induction onto LAAM also may be preferable for certain patients because of logistical considerations. For example, patients with transportation problems or with work-related or other scheduling problems may find LAAM therapy attractive because it reduces the frequency of clinic visits.

Patients who have not had a positive experience with methadone in the past also may prefer direct induction onto LAAM. Although most methadone-maintained patients experience a very stable 24-hour dose response, some patients' response to methadone may fluctuate during a 24-hour period, perhaps because of fluctuations in blood levels of methadone caused by individual differences in metabolism. These patients may benefit from the longer action and more stable dose response to LAAM over the 48- or 72-hour period between doses.

Induction onto a stabilizing regimen of methadone before LAAM treatment is begun affords clinicians the ability to observe the patient on a daily basis. Such an approach can be helpful if the patient is dependent on other drugs, including alcohol.

Before inducting a patient directly onto LAAM, staff should consider other factors. Some patients may desire or need daily contact with staff early in treatment. Patients who need such contact, whether for medical or psychiatric reasons, as well as those who may need medication readjustment, might be cautioned against entering directly into LAAM therapy from street opiate use. These patients can be seen at the clinic on nondose days. Active alcoholics, as well as persons who abuse other sedative-hypnotics, also merit special attention.

Nonetheless, if the patient strongly desires to begin treatment with LAAM and treatment staff believe that it is in the patient's interest to do so, a treatment plan may be developed that permits this option. Arrangements could be made, for example, for daily clinic visits. The drug administration schedule need not govern the frequency of patient contact.

Patients Who Need Daily Contact with StaffIf a patient needs daily contact with staff early in treatment for medical or psychiatric reasons, arrangements can be made for patients to visit the clinic daily if necessary. The drug administration schedule need not govern the frequency of patient contact.

### Switching From Methadone to LAAM

Once LAAM becomes available in an opioid substitution therapy program, all patients should be educated about the new medication and provided as much information as possible. Some guidelines for switching patients from methadone to LAAM are offered; however, clinical judgment should prevail in individual cases.

Patients who are stable. A patient who is eligible for LAAM therapy and is stable on methadone maintenance might be considered for a change to LAAM. Such individuals often do well on LAAM. Acceptance of the medication is generally greater in patients with better psychosocial functioning. Some of these patients describe a "smoother" effect with LAAM as well as a decreased narcotic effect.

Patients who are not progressing well. Patients who are not doing well on methadone may also be considered for LAAM therapy. This may be the case, for example, for certain patients who assimilate methadone quickly and who consequently use heroin as a supplement. Although the use of LAAM may be an appropriate option in these situations, other options, such as increasing the methadone dose, should also be considered.

Noncompliant patients. Some patients receive methadone maintenance for years with little progress. They do not comply with their treatment plan and chronically cause problems and disruptions in program routine. Take-home doses of methadone are not an option for these patients. A change to LAAM may be an option. It is possible that a new medication will offer therapeutic benefits to the patient and reduce disruptions in program routine caused by the daily visits of a problematic patient. As discussed above, patients in this group who are tried on LAAM therapy should be carefully selected and monitored.

When patients are noncompliant and disruptive to clinic routines, staff should begin by counseling the patient about the effects of his or her conduct on clinic morale and operations. Efforts should be made to identify the reasons for the patient's conduct and to resolve them. Should this fail, staff may discuss treatment options, including referral to other treatment modalities in addition to LAAM.

### Initial Dose

The process of induction onto LAAM therapy is essentially the administration of a safe initial dose, which is given to relieve the signs and symptoms of withdrawal and abstinence. Additional doses are adjusted up or down in an effort to approximate the established tolerance threshold of each patient to prevent further symptoms and to reduce or eliminate the desire or craving to continue use of illicit drugs.

During induction onto LAAM, patients may need reassurance that more time, rather than more medication, is needed if full relief is not felt within 48 hours. After all three LAAM compounds have become active and steady state has been achieved, their combined activity produces what many patients describe as feeling more "normal."

A later phase of induction involves slower, more gradual dose adjustments to establish an adequate maintenance dose that ensures the desired effects for the individual patient. The initial dose is determined by the patient's degree of tolerance.

An induction chart is provided in Exhibit 3-2. The chart is for reference only. No such chart can replace direct communication between patient and clinician. Clinicians must speak directly to a patient and to others involved in the patient's care to determine the patient's individual reactions to the medication and to adjust the dosage accordingly.

Exhibit 3.2 Phases of LAAM Dosing

Phase | Purpose | Range in Milligrams
Initial dose | Relieve abstinence symptoms | 20-40 mg
Early induction | Reach tolerance threshold | Plus or minus 5-10 mg q dose
Late induction | Establish adequate dose (desired effects) | Plus or minus 5-10 mg q 5-10 days
Maintenance | Maintain desired effects (steady-state occupation of opiate receptors) | Usually 60-60-60 to 140-140-140 mg or 130-130-180 mg. May be greater than 140 or less than 60 mg

For opiate-addicted persons who are not in treatment, the initial dose of LAAM is 20 to 40 mg. Patients who are stabilized on methadone are crossed over to LAAM at a starting dose equal to 1.2 to 1.3 times their daily methadone dose, not to exceed 120 mg. Subsequent doses may be adjusted by 5 to 10 mg until the patient is stable. Doses should not exceed 140 mg. If a dose of more than 140 mg is prescribed, it must be justified in the medical record, 21 C. F.R. Part 291 Section 291.505(k)(1)(D) (1993).

Especially during induction onto LAAM, patients may need explanation and reassurance that more time, rather than more medication, is needed if full relief is not felt within 48 hours. After all three LAAM compounds have become active and steady state has been achieved, their combined activity produces what many patients describe as feeling more "normal."

### Induction Schedule

In contrast to methadone, which acts quickly in the body, patients may not feel the full benefit of the initial LAAM dose for 6 to 8 hours, until the body metabolizes LAAM into nor-LAAM and dinor-LAAM. Because of this slow onset of effect, patients on LAAM may experience symptoms of withdrawal between scheduled LAAM doses during the induction phase.

Although Federal regulations prohibit LAAM from being given more frequently than every other day, methadone is an appropriate and effective supplement because of its relatively rapid onset of activity (2 to 4 hours). During the induction period, patients can be given small doses of methadone (10 to 20 mg) on days they do not receive LAAM to provide more rapid relief of any discomfort and reduce the risk that they will use illicit drugs. Persistence of withdrawal symptoms indicates that the LAAM dose is inadequate, and the induction schedule should be adjusted accordingly.

Throughout LAAM therapy, particularly during the first 2 weeks of induction, patients need a great deal of reassurance, support, and information. To a large extent, the successful implementation of treatment with LAAM depends on having well-trained staff who are available to support and educate patients. Clinical trials with LAAM showed that when program staff did not accept LAAM therapy as a potential alternative to methadone treatment or were not properly informed about counseling and casework issues, patients also tended not to accept LAAM.

## Maintenance on LAAM

The goal of maintenance treatment is to develop and implement a rehabilitation program that recognizes the chronic, relapsing nature of opiate addiction and allows adequate time to ensure successful long-term remission of the addictive disorder. The treatment plan should be based on the clinical needs of the patient. Arbitrary time limits to a treatment episode are counterproductive and contrary to established principles of high-quality care. Treatment decisions should be based on ongoing dialogue between the patient, counselor, and members of the treatment team.

As is the case for methadone and other medications, the use of LAAM requires ongoing assessment and review of the treatment plan. At a minimum, FDA regulations require that treatment plans be reviewed every 90 days for the first year and every 180 days thereafter. Patient contact with treatment staff should occur as frequently as treatment plans require, and contact should be no less frequent than monthly.

### Maintenance Dose Determination and Dose Adjustments

Decisions about LAAM dosages should be made on a patient-by-patient basis. Extensive research shows that inadequate dosages of methadone play a significant role in the continued abuse of illicit drugs. In clinical trials, this was also true of LAAM; therefore, each patient's LAAM dosage should be sufficient to suppress drug withdrawal symptoms, illicit drug-seeking behavior and use, and associated high-risk behavior.

### Scheduling

A key issue in treatment planning is dose scheduling. LAAM doses can be given either every other day or three times a week (two 48-hour doses and a 72-hour dose). However, every-other-day LAAM dosing is an option only if the clinic is open on Sunday--that is, 7 days a week. Monday-Wednesday-Friday schedules are often convenient for clinic operation and provide the patient with a weekend with no required clinic visit. In practice, the administration schedule for LAAM may be set to fit the clinic's convenience. As far as possible, however, it should also be tailored to the individual patient's comfort, convenience, and other needs.

A key issue in treatment planning is dose scheduling. LAAM doses can be given either every other day or three times a week (two 48-hour doses and a 72-hour dose). However, every-other-day LAAM dosing is an option only if the clinic is open on Sunday--that is, 7 days a week.

Clinical experience with LAAM to date indicates that patients enjoy having weekends without a trip to the clinic and that nearly all patients do extremely well on a 48-hour interval. However, the 72-hour interval, from Friday to Monday, is a problem for some patients who may experience some discomfort, usually late on Sunday, or whose anxiety about the 72-hour interval becomes a clinical issue. A primary task of the counselor is to educate and reassure the patient about LAAM's long-acting nature.

While a few patients take the same LAAM dose on Monday, Wednesday, and Friday, most will benefit from an increase in LAAM on Friday (10 to 40 percent more than the Monday and Wednesday doses) or an increase in LAAM on Friday and a small dose of methadone to be taken home and used on Sunday. For very stable and reliable patients, the best option may be a regular LAAM dose on Friday and a full methadone dose (80 percent of the LAAM dose) as a take-home dose for Sunday.

Exhibit 3-3 shows a chart used by one clinic to calculate the correct dose of LAAM and of methadone for patients on a Monday-Wednesday-Friday LAAM dosing schedule. For example, a patient on 100 mg of LAAM who is allowed take-home doses of methadone would be given a 100-mg dose of LAAM on Monday and Wednesday; on Friday the patient's LAAM dose would increase by 20 percent and he or she would take home a methadone dose of 30 mg for Sunday. As shown in the chart, for patients for whom take-home methadone is not appropriate, the approach is to increase the Friday dose of LAAM by 30 percent to cover the 72-hour period during which the patient receives neither LAAM nor methadone. (According to Federal regulations and most State regulations, all patients are eligible for one take-home dose of methadone. However, the program may decide not to allow a patient to take home any doses.)

Exhibit 3.3 Sample Monday-Wednesday-Friday Dose Scheduling Chart

Sample Monday-Wednesday-Friday Dose Scheduling Chart for Patients on LAAM Who Are and Are Not Allowed Take-Home Methadone
140 | 140 | 168 | 42 | | 140 | 140 | 182
135 | 135 | 162 | 41 | | 135 | 135 | 176
130 | 130 | 156 | 39 | | 130 | 130 | 169
125 | 125 | 150 | 38 | | 125 | 125 | 163
120 | 120 | 144 | 36 | | 120 | 120 | 156
115 | 115 | 138 | 35 | | 115 | 115 | 150
110 | 110 | 132 | 33 | | 110 | 110 | 143
105 | 105 | 126 | 32 | | 105 | 105 | 137
100 | 100 | 120 | 30 | | 100 | 100 | 130
95 | 95 | 114 | 29 | | 95 | 95 | 124
90 | 90 | 108 | 27 | | 90 | 90 | 117
85 | 85 | 102 | 26 | | 85 | 85 | 111
80 | 80 | 96 | 24 | | 80 | 80 | 104
75 | 75 | 90 | 23 | | 75 | 75 | 98
70 | 70 | 84 | 21 | | 70 | 70 | 91
65 | 65 | 70 | 20 | | 65 | 65 | 85
60 | 60 | 72 | 18 | | 60 | 60 | 78
55 | 55 | 66 | 17 | | 55 | 55 | 72
50 | 50 | 60 | 15 | | 50 | 50 | 65
45 | 45 | 54 | 14 | | 45 | 45 | 59
40 | 40 | 48 | 12 | | 40 | 40 | 52
37 | 37 | 44 | 11 | | 37 | 37 | 48
34 | 34 | 41 | 10 | | 34 | 34 | 44
31 | 31 | 37 | 9 | | 31 | 31 | 40
28 | 28 | 34 | 9 | | 28 | 28 | 36
25 | 25 | 30 | 8 | | 25 | 25 | 33
22 | 22 | 26 | 7 | | 25 | 25 | 29
20 | 20 | 24 | 6 | | 20 | 20 | 26
18 | 18 | 22 | 6 | | 18 | 18 | 23
16 | 16 | 19 | 5 | | 16 | 16 | 21
14 | 14 | 17 | 4 | | 14 | 14 | 18
12 | 12 | 14 | 4 | | 12 | 12 | 16
10 | 10 | 12 | 3 | | 10 | 10 | 13
8 | 8 | 10 | 3 | | 8 | 8 | 10
6 | 6 | 7 | 2 | | 6 | 6 | 8
4 | 4 | 5 | 1 | | 4 | 4 | 5
2 | 2 | 2 | 1 | | 2 | 2 | 3
0 | 0 | 0 | 0 | | 0 | 0 | 0

* Friday (72-hour) dose = 20 percent increase over Monday and Wednesday (48-hour) doses

** Methadone dose = 30 percent of Monday and Wednesday (48-hour) doses

*** Friday (72-hour) dose (with no methadone) = 30 percent increase over Monday and Wednesday (48-hour) doses

Not enough data are available to determine whether the optimal clinical benefit of LAAM is achieved with an every-other-day or a three-times-weekly schedule. More studies are needed to elucidate this point. For opioid substitution therapy programs, the currently approved LAAM dosing schedules raise both clinical and practical issues that should be explored.

### Treatment Interruptions

Treatment programs should have plans in place to handle expected or unexpected interruptions in therapy, whether these breaks are short or long. Many circumstances, such as work-related travel, illness, funerals, planned vacations, and emergencies may arise that require patients to miss clinic visits. If it is impossible to maintain an every-other-day or three-times-weekly schedule of LAAM, methadone should be substituted to allow patients to continue treatment without interruption for absences of more than 3 days from LAAM. Because current FDA regulations do not allow take-home doses of LAAM, treatment programs should have methadone available.

### Unplanned Interruptions

Disability or illness. When patients are unable to come to the clinic on their own or to be brought there with assistance because of disability or illness, authorized clinic staff can use curbside delivery and observed-dose procedures to ensure continuity of treatment. Because LAAM and methadone are tools in a comprehensive treatment program, clinics should evaluate the need for continuity of support services as well as medication in these circumstances.

### Missed Doses

When doses are missed, it is critical for the clinician to evaluate the patient to determine the patient's present condition. Has the patient been using illicit drugs or taking other medications? Clear guidelines are available about the clinical management of patients who have missed scheduled LAAM doses:

LAAM dosing options for the 72-hour (Friday to Monday) interval include one of the following:

- An increase in LAAM on Friday: 10 to 40 percent more than the Monday and Wednesday doses
- An increase in LAAM on Friday and a small dose of methadone to be taken home and used on Sunday
- A regular LAAM dose on Friday and a full methadone dose (80 percent of the LAAM dose) as a take-home dose for Sunday (only for very stable and reliable patients).

One dose missed. For patients who miss one scheduled dose and come to the clinic the next day (that is, 3 to 4 days after the last LAAM dose), the preceding day's dose should be given and the rest of the week's schedule should be changed accordingly with a return to the regular schedule the following week. For example, for a patient on a Monday-Wednesday-Friday schedule who misses the Monday dose and comes in on Tuesday, the schedule is changed to Tuesday-Thursday-Saturday for that week only and returns to the regular schedule the following week.

For patients who miss a dose and come to the clinic 2 days later, when their next scheduled dose is due (that is, 4 to 5 days after their last LAAM dose), the scheduled dose is usually well tolerated. Some clinicians may prefer to reduce the dose slightly (for example, by 5 to 10 mg) and return the patient to a stable dose at the next clinic visit. Good clinical judgment and knowledge of the patient are important factors in this situation.

More than one dose missed. For patients who miss more than one dose, reinduction should begin with an initial dose of one-half to three-quarters of the previous dose. Tolerance to LAAM begins to drop to some extent, so that a full dose given after more than one missed dose could result in some degree of impairment or intoxication. LAAM can then be increased by 5 to 10 mg every scheduled day, whether the schedule of administration is every other day or three times a week, until the patient reaches the previous maintenance dose.

More than 1 week off LAAM. For patients who miss more than a week of scheduled LAAM doses, the induction process should be repeated.

### Planned Interruptions

When take-home methadone is used as a supplement to LAAM therapy when interruptions in treatment are anticipated, the number of doses must be calculated carefully so that it is adequate for following the schedule. The first methadone dose should be taken 48 hours after the last observed dose of LAAM, and the last methadone dose should be taken 24 hours before the next scheduled dose of LAAM at the clinic.

Holidays and vacations. For patients taking LAAM every other day, the schedule can be adjusted so that a Monday holiday falls on an "off" day. If the schedule cannot be modified, methadone can be provided at 80 percent of the 48-hour dose, with instructions to take it 48 hours after the last LAAM dose.

For vacation and travel plans, methadone can be substituted for LAAM in the same manner as for a Monday holiday. If 80 percent of the patient's LAAM dose is more than 100 mg of methadone, however, clearance from the State authority and FDA may be necessary because of the dose limit for take-home methadone, 21 C.F.R. Part 291 Section 291.505(d)(6)(iv) (1993). To be compliant, each program must be aware of State-specific regulations in addition to Federal regulations.

Hospitalization. Opioid substitution therapy programs are responsible for ensuring continuity of treatment for patients who are hospitalized. Programs often find provision of this continuity to be a problem, because some hospitals are unfamiliar with or have philosophical or ideological objections to substitution therapy. Although methadone is available in some hospitals for analgesia and to continue maintenance for patients, some specialty hospitals do not even stock methadone. Hospitals initially will not carry LAAM, and methadone will have to be substituted. They may need to consult program staff on the appropriate conversion dose of methadone to substitute for LAAM. Programs should explore ways to educate hospitals and treating physicians in their communities about the needs of LAAM-maintained patients.

Federal regulations state that "Hospitalized patients under care for a medical or surgical condition are permitted to receive LAAM in oral form when the attending physician judges it to be advisable." In such cases, authorized clinic personnel can deliver and administer LAAM to their patients. If the attending physician does not permit the use of LAAM, the patient can be transferred to methadone, which most hospital pharmacies can provide. If doubt about the legality of providing LAAM or methadone remains after hospital staff have seen the pertinent Federal regulations, the State authority can be contacted for verification.

The best practice is for clinic staff to stay in touch with and be involved in the education of the patient's hospital clinician. For example, hospital house staff may not be aware that certain drugs, such as a mixed agonist and antagonist for pain management, should not be prescribed for patients receiving LAAM or methadone. (See Chapter 1 for more information about pain management in LAAM-maintained patients.) Communication between program and hospital staff raises confidentiality issues, and information about confidentiality should be included in treatment programs' educational presentations to the health care community. The patient's consent is necessary for this kind of program-hospital communication, but a medical emergency supersedes confidentiality regulations. If it is conducted professionally and with linkage and cooperation as goals, this kind of coordination of care can enhance the status of treatment program personnel with hospital staff.

When patients on LAAM are hospitalized, authorized clinic personnel can deliver and administer LAAM. If the attending physician does not permit the use of LAAM, the patient can be transferred to methadone, which most hospital formularies can provide.

Hospitalization, particularly of unconscious patients, raises the issue of the use of identification (ID) cards. ID cards, in turn, raise privacy issues. One large urban opioid substitution therapy program provides patients with a photographic ID card to gain admittance to the clinic. The program's experience is that some patients use their clinic card as a generic photographic ID in lieu of a driver's license; for example, they use it to cash checks, despite the fact that the card identifies them as being in treatment. "Smart cards" containing a complete medical history are already in use in the United States, Israel, and Holland and may be useful in opioid substitution therapy programs. These cards would contain electronically encoded information needed by the program to identify and monitor the patient; they would not outwardly identify the card holder as a patient.

### Overdose

LAAM's long-acting characteristics have critical implications for the treatment of overdose or oversedation, which is more likely to occur in new patients than in dose-stable patients. Almost all overdoses in LAAM patients involve a combination of sedative drugs. In such cases, the ABCD approach is appropriate for first aid:

- A - Airway: make sure it is clear.
- B - Breathing: ensure adequate breathing and ventilation.
- C - Cardiac: check cardiac status and ensure circulation.
- D - Drugs: Use naloxone if needed (an opioid antagonist) to counter the effects of LAAM.

In the standard treatment of overdose, naloxone may be administered. If naloxone is used, however, it is important to recognize that LAAM is long acting (effective for up to 48 hours) and naloxone is short acting (effective for .5 to 1 hour). This difference in duration of action means that the patient may respond to naloxone initially and then lapse into coma again when the effects of naloxone wear off but the effects of LAAM remain. For this reason, patients who have overdosed should be kept under observation for a minimum of 48 hours and given repeat naloxone by injection or continuous drip as needed. If a patient who has overdosed is hospitalized, house physicians may need to be educated about the different duration of activity of LAAM and naloxone. Programs should ensure that emergency services in their areas have the latest outlines for treating clients who are on LAAM for medical emergencies and who have had overdoses related to opiates, cocaine or crack, alcohol, or prescription medications.

## Withdrawal and Termination From LAAM Therapy

Few studies have addressed the medically supervised withdrawal of LAAM patients to a drug-free state. No evidence exists, however, to suggest that withdrawal from LAAM is different from withdrawal from methadone or any other opioid. Because patient motivation is essential to success, it is very important that patients initiate the process. Any patient who asks to be withdrawn from LAAM has the right to a medically supervised withdrawal program. The decision to withdraw from LAAM treatment is a highly complex process that should take into account several factors, including level of stability, past levels of functioning without medication, and fear of detoxification (Moolchan and Hoffman, 1994).

Withdrawal and termination from LAAM therapy are highly patient-specific processes. For the LAAM-maintained patient who is psychosocially rehabilitated and wishes to achieve drug-free status, the LAAM dose can be reduced gradually at a rate determined by the patient's response. The LAAM dose levels presented in Exhibit 3-3 (earlier in this chapter) show an example of such a gradual reduction.

Clinic staff should be aware that patients often have a great fear of protracted periods of withdrawal. Because LAAM is longer acting than methadone, withdrawal is expected to have a delayed onset and protracted course, although the withdrawal may be less intense than with other opioids. Patients, however, tend to perceive a longer period as being worse, whether the actual intensity of symptoms is greater or not. Special counseling may be needed to address this aspect of withdrawal from LAAM.

For patients who wish to achieve drug-free status

- The LAAM dose can be reduced gradually at a rate determined by the patient's response.
- Patients who prefer a less protracted withdrawal phase can be converted to methadone treatment and then tapered off methadone.

As an alternative, patients who want to withdraw from LAAM treatment can be switched to methadone and then have their medication tapered. They can be transferred to methadone at 80 percent of their LAAM dose with minimal difficulty. The key issue in this decision may be the support system the patient needs; take-home methadone entails fewer clinic visits. Although patients can visit the clinic on nondose days for support services only, they are less likely to do so without the incentive of receiving a medication dose.

When involuntary withdrawal from medication is unavoidable, patients should be transferred to methadone before withdrawal is begun so that they can be observed on a daily basis and because clinical experience with methadone withdrawal is more extensive. Also, because of the shorter half-life of methadone, it may be possible to withdraw a patient more rapidly from methadone, a course which is usually desirable in involuntary situations.

When a patient knows that he or she must serve time in jail or prison, such a planned withdrawal is best. Only one jail facility in the country - Rikers Island, the central jail facility in New York City - is known to provide methadone maintenance. Most jails do not even provide methadone for detoxification. When a patient is arrested, program staff should make every effort to communicate with criminal justice authorities and to recommend that the patient be withdrawn over a period of time. Whether the patient is maintained on LAAM or methadone, some form of maintenance or detoxification is preferable to sudden withdrawal of the medication.

The decision to terminate treatment with LAAM involves the same considerations as the decision to terminate treatment with methadone. Patients should be encouraged to stay in treatment as long as necessary to allow them to make the therapeutic changes that will support a drug-free lifestyle. Patients should not be pressured to discontinue treatment to meet arbitrary deadlines. There is no evidence that any specific duration of therapy is an adequate treatment "dose." The decision to attempt to withdraw from LAAM treatment should be made jointly by the patient and the treatment team.