# Chapter 2 - Clinical Profile of LAAM

LAAM (levo-alpha-acetyl-methadol) is a synthetic opioid agonist that has recently been approved by the Food and Drug Administration (FDA) for the maintenance treatment of opiate addiction (Food and Drug Administration, 1993). It is not approved for opiate detoxification treatment for either short- or long-term detoxification.

Although LAAM is similar to methadone in many ways, it has several features that make it distinct from methadone. The most significant of these features is LAAM's longer duration of action, which allows patients to visit the treatment program less frequently from treatment inception. The approval of LAAM provides a new treatment alternative in the management of opiate addiction. As such, it should be evaluated by the same standards by which other treatment options have been judged. A new medication should, for example, expand accessibility to treatment, and it should enable more effective and appropriate treatment for patients already in the treatment system. LAAM therapy offers patients such possibilities and creates opportunities for staff members to learn about and provide a new form of care.

In approving LAAM, FDA did not significantly modify the language of the regulations governing methadone treatment. The word "methadone," for example, was simply changed to "narcotic drugs" to be more inclusive. However, differences between the two agents with respect to dosing schedules, prohibition of LAAM take-home doses, and eligibility for LAAM treatment are spelled out in detail in the FDA regulations. As the States begin to approve LAAM and develop their own regulations, many may wish to follow the Federal example. Introduction of LAAM does not require States to develop extensive new regulations. (See Chapter 6 for a discussion of regulations and their development.)

This chapter describes the medication LAAM, including its metabolization, interactions with drugs of abuse and other medications, safety and side effects, and use with certain patient groups, such as women.

Any new medication should expand accessibility to treatment and enable more effective and appropriate treatment for patients already in the treatment system.

## Metabolism and Mechanism of Action

The clinical utility of LAAM is based primarily on the activity of two metabolites, rather than on that of the parent drug alone. In the body, LAAM, metabolized by the liver, changes sequentially to nor-LAAM and dinor-LAAM. (Throughout this document, the term LAAM refers to the parent compound and its two active metabolites, nor-LAAM and dinor-LAAM.) Of these three compounds, nor-LAAM is the most potent. The combined duration of activity of all three of these compounds accounts for LAAM's long-acting properties. Knowledge of the basics of steady-state pharmacology is important for understanding the action of LAAM in the body. Steady-state pharmacology is described in Chapter 3 in the section "Induction Onto LAAM."

In practical terms, LAAM's longer action makes it possible for patients to visit the clinic less often than they would for daily methadone treatment. LAAM can be given either every other day or three times a week. Under current FDA regulations, LAAM cannot be given more frequently than every other day, 21 C.F.R. Part 291 Section 291.505(k)(1)(i) (1993), and no take-home doses can be given under any circumstances, 21 C.F.R. Part 291 Section 291.505 (k)(1)(iii) (1993).

Federal regulations also require clinics that use both LAAM and methadone to ensure that "dosage forms of LAAM and methadone are easily distinguished," 21 C.F.R. Part 291 Section 291.505 (1993). LAAM must be different in color and taste from methadone. Methadone is currently available in powder, tablet, and liquid forms, whereas LAAM is currently prepared only in liquid formulation for oral use. The manufacturer provides LAAM as a colorless liquid.

Clinic staff should ensure that patients who are known to abuse sedatives, tranquilizers, propoxyphene, antidepressants, benzodiazepines, or alcohol are told in very clear language of the dangers of adverse additive effects if they take these substances while maintained on LAAM.

At present, LAAM is available only from Roxane Laboratories, Inc. Methadone can be purchased from three different companies: Mallinckrodt Chemical, Inc.; Roxane Laboratories, Inc.; and UDL Laboratories, Inc. Each company markets different forms of methadone that vary in color and taste from the others.

## Drug Interactions

### Drugs of Abuse

LAAM's interactions with drugs of abuse have not been systematically studied in human populations, but data from the clinical studies do not suggest any unusual risk of LAAM versus other opiates in terms of drug-drug interactions with drugs of abuse. The effects of LAAM would be expected to be similar to the effects of methadone and other opioid drugs under the same conditions. However, until conclusive data from systematic studies are available, interactions cannot be predicted with certainty.

LAAM, like methadone and other opioids, may have additive or synergistic effects when used in combination with commonly used drugs of abuse. Because of LAAM's long-acting nature, both patients and clinic staff should be aware that special caution is necessary when it is combined with drugs that depress the central nervous system, including alcohol. For this reason, clinic staff should ensure that all patients who are known to abuse sedatives, tranquilizers, propoxyphene, antidepressants, benzodiazepines, or alcohol are told in very clear language of the dangers of adverse additive effects if they take these substances while being stabilized or maintained on LAAM.

Experience during the Labelling Assessment Study (LAS) of LAAM indicated that LAAM's delayed onset of effect (from 24 to 36 hours) may lead some patients to take benzodiazepines or other drugs including opiates in an attempt to create an additive effect. Patients receiving LAAM should be counseled very specifically about its delayed onset and prolonged duration of activity, as well as the associated extra risk of effects that can induce withdrawal if patients take other drugs, even on days when they do not receive a LAAM dose. Some patients may not be candidates for LAAM if they are unable to tolerate the slow onset.

Patients receiving LAAM should also be cautioned not to use or abuse alcoholic beverages. Patients should be advised that chronic use of alcohol damages the liver and that liver dysfunction may interfere with the metabolism of LAAM. If alcohol abuse is evident, the program should ensure that the patient receives counseling and assistance in discontinuing alcohol use. If a patient abuses alcohol consistently, a switch to methadone may be warranted because daily clinic attendance will permit closer monitoring, and research has indicated that methadone may be safely prescribed for patients with severe liver damage. Although similar research on LAAM has not been completed, there is every reason to believe that use of LAAM by patients with severe liver damage is not problematic. LAAM may be used concurrently with disulfiram (Antabuse).

### Medications That Can Induce Withdrawal

Mixed agonists and antagonists, such as pentazocine (Talwin), butorphanol (Stadol), nalbuphine (Nubain), and buprenorphine (Buprenex), and pure antagonists, such as naltrexone and naloxone, all may precipitate withdrawal in LAAM-maintained patients. FDA has recently approved the narcotic agonist naltrexone for use in treating alcohol craving. Clinicians must be aware and must inform patients that the use of naltrexone will precipitate withdrawal symptoms in patients maintained on LAAM or methadone. Naltrexone must not be used by patients in opioid substitution therapy.

### Cross-tolerance

As a result of cross-tolerance, LAAM (like other mu agonists) reduces the effectiveness of narcotic analgesics in normal doses. Clinicians may need to adjust medications and patient pain management accordingly. As with methadone, when other narcotics, such as morphine, are used for analgesia and anesthesia, dosages should be adjusted upward to achieve the same level of pain relief or anesthesia.

Clinicians must be aware and must inform patients that the use of naltrexone for treatment of alcohol craving will precipitate withdrawal symptoms in patients maintained on LAAM or methadone. Naltrexone must not be used by patients in opioid substitution therapy.

### Interaction With Antituberculosis Drugs and Other Medications

With the rise in the prevalence of tuberculosis, many more patients are being prescribed rifampin, the bactericidal drug currently widely used to treat this disease. Rifampin has been found to reduce methadone levels in serum by up to 50 percent in patients who have been stabilized on methadone maintenance. This reduction in serum levels of methadone often results in symptoms of withdrawal. A recent study of an alternate antituberculosis medication, mycobutin (Rifabutin), showed that this medication did not alter plasma levels of methadone. Some participants had subjective complaints of discomfort, which may have resulted from suggestivity to remarks of the researchers, as noted at the consensus panel by B. Primm, M.D. Further studies of this type should be effects.

When a new medication is introduced to the market, all potential side effects must be reported. The most frequently reported side effects in the LAAM trials were insomnia, nervousness, and constipation. Other side effects observed in clinical trials are shown in Exhibit 2-1. Side effects probably caused by LAAM that occurred in less than 1 percent of patients in clinical trials include a drop in blood pressure when the patient stands (postural hypotension), muscle pain (myalgia), and tearing of the eyes.

In addition, several other reactions appeared in both controlled and uncontrolled LAAM trials. Although they were seen infrequently and their relationship to LAAM is unknown, clinic staff should be aware that these effects have been reported: hypertension, changes in cardiac activity patterns on electrocardiogram (specifically, prolongation of the QT interval and nonspecific ST-T wave changes), bradycardia, hepatitis and test indications of abnormal liver functions, absence of menstruation (amenorrhea), and the presence of pus in the urine (pyuria). Close monitoring by counselors, nurses, and medical staff in the first several months of adjustment to LAAM therapy will ensure that any side effects are addressed promptly.

Exhibit 2.1 Possible Side Effects of LAAM

Whole body | Respiratory
Weakness, loss of energy (asthenia)^1^ | Cough^2^
Back pain^2^, chills^2^ | Rhinitis^2^
Fluid accumulation (edema)^2^ | Yawning^2^
Hot flashes (males 2:1)^2^
Flu syndrome and malaise (11 percent) | Cardiac
| Hypertension^3^
Gastrointestinal | Electrocardiogram (EKG) changes^3^
Abdominal pain^1^ | Postural hypotension
Constipation^1^ | Slowed heart rate (bradycardia)
Diarrhea^2^
Dry mouth^2^ | Hepatic
Nausea and vomiting^2^ | Hepatitis^3^
| Abnormal liver function tests^3^
Musculoskeletal
Joint pain (arthralgia)^1^ | Skin and Appendages
Muscle pain (myalgia) | Rash^2^
| Sweating^1^
Nervous System
Abnormal dreams^2^ | Special Senses
Anxiety^2^ | Blurred vision^2^
Decreased sex drive^2^ | Tearing
Depression^2^
Euphoria^2^ | Urogenital
Headache^2^ | Difficult ejaculation^1^
Decreased sensitivity to stimulation (hypesthesia)^2^ | Impotence^1^
Insomnia (9.1 percent) | Absence of menstrual periods (amenorrhea)3
Nervousness^1^ | Pus in the urine (pyuria)^3^
Sleepiness, unnatural drowsiness (somnolence)^2^

1 Side effects occurred in more than 3 to 9 percent of patients and were probably related to LAAM.

2 Side effects occurred in 1 to 3 percent of patients and were probably related to LAAM.

3 Side effects occurred with "low frequency in controlled and uncontrolled studies. They are not known to be causally related to the administration of the drug."

Side effects with no superscript occurred in less than 1 percent, unless otherwise indicated.

Adapted from ORLAAM: Levo-alpha-acetyl-methadol for the Management of Opiate Dependence: Information for Physicians. No date.

### Interventions

Clinicians may want to provide symptomatic treatment of side effects resulting from LAAM. Of the three most commonly reported side effects of LAAM, constipation is probably the most persistent and problematic. It also raises the potential problem of laxative dependence when patients treat themselves. Patients should be told to avoid the use of strong or harsh chemical laxatives. Stool softeners, lubricants (such as mineral oil), bulk and fiber laxatives (such as Metamucil), and naturally occurring laxatives such as prunes may provide symptomatic relief. However, it should be noted that chronic use of mineral oil can lead to malabsorption of fat-soluble vitamins and result in a vitamin deficiency. Adequate fluid intake also is important.

The other two most frequent reactions to LAAM therapy, insomnia and nervousness, usually disappear with continued treatment. Other side effects, for example, muscle and joint pain, can be treated with nonsteroidal anti-inflammatory agents, such as ibuprofen.

Until the safety of LAAM during pregnancy is studied further, the consensus panel recommends that women of childbearing potential who enter treatment receive methadone rather than LAAM. Once treatment has progressed, the required pregnancy testing can be discussed with the patient. When informed consent is obtained and pregnancy testing is implemented, the woman can be transferred to LAAM if this is desirable.

### Possible Impact of Liver Disease

Further research is needed on the impact of liver disease on patients in opioid substitution therapy programs. Although the presence of liver disease is not currently a reason to exclude a patient from treatment, the presence of severe persistent liver disease does indicate the need for caution in treatment and monitoring and may require special patient counseling. In patients with a severely impaired liver, the parent drug, LAAM, may not be as easily converted into the more active metabolite, nor-LAAM, because this process occurs in the liver. This difficulty in conversion could delay the drug's onset of effect. Such patients should be monitored closely for signs of excessive accumulation of LAAM and its metabolites.

Patients should also be monitored for signs and symptoms of dose accumulation, which include jumpiness or feeling on edge (what some patients describe as "feeling wired"), poor concentration, drowsiness, and dizziness when moving to a standing position. When patients exhibit signs of excess accumulation of LAAM, the dosage should be reduced. If significant signs of sedation are present, the clinician may omit a dose or slow the buildup.

## Effects of LAAM Treatment in Specific Clinical Situations and Patient Populations

### Women

Data show no differences between the sexes in response to LAAM treatment; women and men fare equally well. However, until the safety of LAAM during pregnancy is studied further, the consensus panel that developed this Treatment Improvement Protocol felt that women of childbearing potential who entered treatment should receive methadone rather than LAAM. Once treatment has progressed, the required pregnancy testing can be discussed with the patient. When informed consent is obtained and pregnancy testing is implemented, the woman can be transferred to LAAM if this is desirable. As discussed in Chapter 1, the panel recommends that the necessary studies in animals and humans be conducted and evaluated quickly and the results made widely available to patients, clinicians, and administrators. If warranted, the current requirement for monthly testing should be revised based on these studies.

Until data are evaluated, treatment of pregnant women with LAAM is discouraged. Monthly pregnancy testing is a requirement for women of childbearing potential who receive LAAM. Women who become pregnant while on LAAM should be transferred to methadone maintenance. (More detailed information about considerations for pregnant women and nursing mothers is given in Chapter 3.)

Currently, there is no known reason to exclude patients from LAAM treatment based on HIV-positive status or AIDS.

### HIV-Infected Patients

The effect of LAAM on the immune system is unknown, as is its interaction with zidovudine (formerly azidothymidine, or AZT) and other drugs prescribed for patients with human immunodeficiency virus (HIV) infection and acquired immunodeficiency syndrome (AIDS). Currently, there is no known reason to exclude patients from LAAM treatment based on HIV-positive status or AIDS.

### Pain Management in LAAM-Maintained Patients

Patients receiving maintenance therapy with methadone or LAAM are often undertreated or even denied treatment for pain associated with injury, surgical procedures, or chronic conditions. It is the ethical obligation of health care providers to provide adequate pain relief for all patients. Reluctance to provide adequate treatment for pain is usually based on the belief that the maintenance dose of LAAM or methadone provides pain relief. This belief is absolutely incorrect. With long-term administration of LAAM, nearly complete tolerance develops to any analgesic effects of the medication, and the usual maintenance dose affords no pain relief.

Reluctance to provide adequate treatment for pain is usually based on the belief that the maintenance dose of LAAM or methadone provides pain relief. This belief is absolutely incorrect. With long-term administration of LAAM, nearly complete tolerance develops to any analgesic effects of the medication, and the usual maintenance dose affords no pain relief.

The inadequate treatment of pain in patients receiving maintenance therapy often leads to disruptive behavior by angry and frightened patients and discharge against medical advice, despite the obvious risks to the health of the patient (Zweben and Payte, 1990). For these reasons, program staff should work cooperatively with the patient's health care providers to assist in providing proper pain management and treatment.

#### Acute Pain

Patients on LAAM maintenance therapy for opiate addiction occasionally require treatment for pain associated with trauma or with medical, surgical, or dental procedures. Whenever possible, pain management should be discussed with care providers before surgery or dental procedures take place. Some basic principles should inform the management of acute pain in patients receiving maintenance therapy:

1. Maintenance treatment should be continued without interruption during pain management.
2. When nonnarcotic analgesia is not effective for pain management, standard opioid agonist drugs, such as codeine and morphine, are appropriate. It is important, however, for clinicians to be aware that patients will require higher doses of these drugs at more frequent intervals because of cross-tolerance to LAAM or methadone. Doses should be adjusted accordingly to achieve adequate pain relief for the patient. Doses should be administered at regular intervals rather than "as needed."
3. Agonist/antagonist drugs may precipitate severe withdrawal reactions and should not be used. These include pentazocine (Talwin), butorphanol (Stadol), nalbuphine (Nubain), buprenorphine (Buprenex), and naltrexone. More information on this subject can be found in the TIP State Methadone Treatment Guidelines.

#### Chronic Pain

Patients with chronic opioid addiction and a disorder causing chronic pain pose a clinical challenge. Those who fail to respond to more conservative management often benefit from carefully supervised adequate doses of short-acting opioid agonist drugs, provided within the context of adequate dose maintenance pharmacotherapy.

## Issues for Further Research

The two most important areas for additional research on LAAM treatment are pregnancy (effects on the mother and the fetus, including postpartum issues such as lactation and breast-feeding) and the feasibility of take-home LAAM. Other essential research topics related to LAAM are

1. Immune response
2. Interactions with drugs of abuse, such as cocaine and alcohol (multidrug interactions)
3. Coexisting psychological problems or disorders (dual diagnoses)
4. LAAM as an analgesic for treatment of chronic pain
5. Interactions with other therapeutic drugs
6. Medically supervised withdrawal from maintenance therapy with LAAM
7. LAAM in patients with hepatic or renal disease
8. LAAM for daily use in special situations, such as in patients who metabolize the drug rapidly.

Other research areas include quality assurance studies focusing on improved treatment outcomes (for example, research on patient selection and on staff attitudes) and cost-effectiveness studies.