# Appendix D - Field Reviewers

- Emizie Abbott, C.C.D.C. III
- Executive Director
- Cleveland Treatment Center, Inc.
- Cleveland, Ohio

- Patrick J. Abbott, M.D.
- Chief Psychiatrist, Methadone Program
- CASAA
- University of New Mexico
- Albuquerque, New Mexico

- Carol Nykerk Abel
- Program Director
- In Jail Intervention Program
- Portland, Oregon

- Robert E. Anderson
- Director, Quality Assurance and Case Management Programs
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.

- Richard J. Bilangi
- President and Executive Director
- Connecticut Counseling Centers, Inc.
- Norwalk, Connecticut

- C. Hope Bolger, R.Ph.
- Methadone Services Consultant
- Department of Mental Health, Mental Retardation and Substance Abuse Services
- Office of Substance Abuse Services
- Richmond, Virginia

- Stephen J. Brummett, M.S.W.
- Program Manager, Alcohol and Drug Treatment Services Division
- Jackson County Alcohol and Drug Treatment Services
- Medford, Oregon

- Gloria Campbell, B.S.
- Policy and Planning Specialist, Maryland Alcohol and Drug Abuse Administration
- Department of Health and Mental Hygiene
- Baltimore, Maryland

- John T. Carroll, M.S., N.C.A.C. II
- Division Director, Substance Abuse Services
- Crozer-Chester Medical Center
- Chester, Pennsylvania

- Richard Christensen, P.A., C.A.S.
- Director of Medical Services
- Valle del Sol
- Phoenix, Arizona

- Addie Corradi
- Associate Commissioner, Division of Health and Planning
- Baltimore, Maryland

- Nancy Jane Heilman, M.S.
- Program Manager
- State Methadone Authority Designee
- Division of Substance Abuse
- New Mexico Department of Health
- Santa Fe, New Mexico

- Jeffrey A. Hoffman, Ph.D.
- Executive Director
- The Koba Institute Center for Drug Treatment and Research
- Washington, D.C.

- Alfonso D. Holliday, II, M.D., M.B.A., A.S.A.M., (Certified)
- President and Medical Director, Methadone Maintenance and Detoxification Program
- Holliday Health Care, P.C.
- Gary, Indiana

- John Langrod, Ph.D., M.S.W.
- Director of Research and Admissions
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, New York

- Thomas La Salvia, M.A., M.P.H.
- Director of Licensing
- Bureau of Substance Abuse Services
- Department of Public Health
- Boston, Massachusetts

- Barbara J. Mason, Ph.D.
- Associate Professor and Director, Division of Substance Abuse
- Department of Psychiatry
- University of Miami School of Medicine
- Miami, Florida

- R. Thomas Mathew, M.D.
- Clinical Assistant, Addiction Services
- Massachusetts General Hospital
- Boston, Massachusetts

- John J. McCarthy, M.D.
- Executive and Medical Director
- Bi-Valley Medical Clinic, Inc.
- Sacramento, California

- Dennis J. McGorman
- Executive Director
- ICI Projects Inc.
- Long Beach, California

- Margaret McIntyre, M.A.
- Assistant Director, Grants and Administration
- Maryland Alcohol and Drug Abuse Administration
- Baltimore, Maryland

- Paul McLaughlin
- Executive Director
- Hartford Dispensary
- Hartford, Connecticut

- A. Les McLemore
- Consultant, Alcohol and Drug Abuse Services Section
- Division of Mental Health/Developmental Disabilities Substance Abuse Services
- Raleigh, North Carolina

- Forrest B. Miller, Jr., M.D.
- Medical Director and Assistant Professor of Pharmacology and Toxicology
- Substance Abuse Treatment Clinic
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas

- Eric T. Moolchan, M.D.
- Director, District of Columbia AIDS Education and Training Center
- Howard University Hospital
- and Assistant Professor of Internal Medicine and Pediatrics
- Howard University College of Medicine
- Washington, D.C.

- Susan F. Neshin, M.D.
- Medical Director
- Jersey Shore Addiction Service, Inc.
- Asbury Park, New Jersey

- Caleb Tyn O. Otto, M.B.B.S., M.H.A.
- Chief, Public Health and Preventive Services
- Division of Behavioral Health
- Bureau of Public Health
- Ministry of Health
- Koror, Palau

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates
- San Antonio, Texas

- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center
- Los Angeles, California

- Nicholas Reuter, M.P.H.
- Consumer Safety Officer, Office of Health Affairs
- Food and Drug Administration
- Rockville, Maryland

- Marianne L. Scheck, R.N., B.S., C.A.D.C. II
- Mental Health Specialist I, Family Support Team
- Children's Services Division
- Marion County Drug Treatment Program
- Salem, Oregon

- Jerome M. Schnitt, M.D.
- Associate Clinical Professor of Psychiatry
- Yale University School of Medicine
- New Haven, Connecticut

- Edward C. Senay, M.D.
- Director
- Interventions Research Institute
- Chesterton, Indiana

- Steven Shoptaw, Ph.D.
- Research Director
- Matrix Center
- Los Angeles, California

- D. Dwayne Simpson, Ph.D.
- Director and Professor, Institute of Behavioral Research
- Texas Christian University
- Fort Worth, Texas

- Merritt A. Smith, M.D., M.P.H.
- Medical Director, Community Substance Abuse Services
- Department of Public Health
- San Francisco, California

- Craig Stenning, M.P.A.
- President and CEO
- CODAC
- Cranston, Rhode Island

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Veterans Health Administration
- Washington, D.C.

- Forest Tennant, M.D., Dr.PH.
- Executive Director, Community Health Project Medical Group
- Research Center
- West Covina, California

- Cemal Unverdi, M.D.
- Assistant Clinical Professor of Psychiatry
- University of Texas
- Southwestern Medical Center at Dallas
- Dallas Veterans Affairs Medical Center
- Dallas, Texas

- Janicemarie K. Vinicky, Ph.D.
- Director, Department of Bioethics
- Washington Hospital Center
- Washington, D.C.

- Frank Vocci, Ph.D.
- Deputy Director, Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland

- Joan E. Zweben, Ph.D.
- Executive Director, The 14th Street Clinic and Medical Center
- The East Bay Community Recovery Project
- Oakland, California