# Appendix C - Federal Resource Panel

- Joseph H. Autry, III, M.D.
- Director, Division of Workplace Programs
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- William Butynski, Ph.D.
- Executive Director, Retired
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.

- James G. Hill
- Director, Office of Substance Abuse
- American Psychological Association
- Washington, D.C.

- Jeffrey A. Hoffman, Ph.D.
- Executive Director
- The Koba Institute Center for Drug Treatment and Research
- Washington, D.C.

- Robert G. Lubran, M.P.A.
- Chief, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Ira J. Marion, M.A. B Chair
- Associate Executive Director, Division of Substance Abuse
- Albert Einstein College of Medicine of Yeshiva University
- Bronx, New York

- J. Wendell McConnell, M.D.
- Chief, HIV/Linkage Branch
- Division of Clinical Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration

- Diedra Roach, M.D.
- Medical Director
- Alcohol and Drug Abuse Services Administration
- Washington, D.C.

- Barbara Roberts, Ph.D.
- Senior Policy Analyst, Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Veterans Health Administration
- Washington, D.C.

- Sylvia Trent-Adams, R.N.
- Public Health Analyst, HIV and Substance Abuse Services Branch
- Division of Programs for Special Populations
- Bureau of Primary Health Care
- Health Resources and Services Administration

- Frank Vocci, Ph.D.
- Deputy Director, Medications Development Division
- National Institute on Drug Abuse

- Linda Wright-DeAguero, Ph.D., M.P.H.
- Research Sociologist, HIV Prevention Among Drug Users Unit
- Division of STD/HIV Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia