# Appendix B - Training Resources

## Roxane Laboratories, Inc.

Roxane Laboratories, Inc., manufacturer of LAAM, provides onsite training to clinics that have received Food and Drug Administration (FDA) approval to administer LAAM. Training can be tailored to address the needs of physicians, nurses, counselors, or administrators. Depending on the needs of the clinic, training may be conducted in a couple of hours or a full day. A number of informational brochures, as well as a videotape, are available for physicians, counselors, and patients. There is no charge for the training. More information can be received by writing to Roxane Laboratories, Inc., P.O. Box 16532, Columbus, Ohio 43216, or by calling (614) 276-4000.

## Single State Agencies and the Opioid Addiction Treatment Improvement Project

CSAT implemented the Opioid Addiction Treatment Improvement Project (OATIP) as a nationwide initiative to enhance the quality and scope of drug treatment for opioid-dependent populations in order to improve treatment effectiveness. The primary purpose of technical assistance to single State agencies is to improve clinical services management, quality assurance activities, evaluation, and compliance with State and Federal regulatory requirements. The services include national technical assistance (onsite and offsite); workshops with State AOD directors, opioid addiction treatment providers, and other key agents in related areas; and information dissemination on opioid treatment.