# Appendix A - Bibliography

Ball, J.C., Ross, A. The Effectiveness of Methadone Maintenance Treatment: Patients, Programs, Services, & Outcome. New York, New York: Springer Verlag. 1991.
Billings, R.E., McMahon, R.E., Blake, D.A. L-acetyl-methadol (LAM) treatment of opiate dependence: plasma and urine levels of two pharmacologically active metabolites. Life Sciences. 1974;14:1437-1446.
Blachly, P.H. L-alpha-acetyl methadol in the treatment of opiate addiction: progress report 1971. In: Rx: 3x/Week LAAM: Alternative to Methadone. Rockville, Maryland: National Institute of Drug Abuse; 1976: 55-56. US Department of Health, Education, and Welfare publication ADM 76-347. NIDA Research Monograph 8.
Blaine, J.D., Renault, P., Levine, G.L., Whysner, J. A. Clinical use of LAAM. Annals of the New York Academy of Sciences. 1978;311:214-231.
Brewer, C. The management of opiate abuse: learning from other addictions. Journal of Drug Issues. 1988;18:679-697.
California Department of Alcohol and Drug Programs. Evaluating Recovery Services: The California Drug and Alcohol Assessment (CALDATA). Sacramento: California Department of Alcohol and Drug Programs. 1994.
Charuvastra, V.C. A US Veterans Administration cooperative study on methadyl acetate. In: International Challenge of Drug Abuse. Rockville, Maryland: National Institute of Drug Abuse, 1976: 260-270. US Department of Health, Education, and Welfare publication ADM 78-654. NIDA Research Monograph 9.
Charuvastra, V.C., Panell, J., Ling, W., Ouren, J. Follow-up study of subjects on methadyl acetate and methadone. Drug and Alcohol Dependence. 1980;6:273-284.
Chinn, D.M. The biodisposition of 1-alpha-acetyl methadol and its principal metabolites: some fatal and nonfatal cases. Journal of Analytical Toxicology. 1979;3:143-149.
Crowley, T.J., Jones, R.H., Hydinger-Macdonald, M.J., et al. Every-other-day acetylmethadol disturbs circadian cycles of human motility. Psychopharmacology. 1979;6:151-155.
Crowley, T.J., MacDonald, M.J., Wagner, J.E., Zerbe, G. Acetylmethadol versus methadone: human mood and motility. Psychopharmacology. 1985;86:458-463.
Desmond, D.P. Effectiveness of psychotherapeutic counseling in methadone maintenance. Drug and Alcohol Dependence. 1979;4:439-447.
Dewey, W.L. Various factors which affect the rate of development of tolerance and physical dependence to abused drugs. In: Mechanics of Tolerance and Dependence. Rockville, Maryland: National Institute of Drug Abuse; 1984: 39-49. US Department of Health and Human Services publication ADM 84-1330. NIDA Research Monograph 54.
Dogoloff, L.I. Toward a coherent system of narcotic addiction treatment. Annals of the New York Academy of Sciences. 1978;311:296-301.
Falek, A., Hollingsworth, F. Heroin and chromosome damage. Archives of General Psychiatry. 1980;37:227-228.
Finkle, B.S., Jennison, T.A., Chinn, D.M., Ling, W., Holmes, E.D. Plasma and urine disposition of 1-alpha-acetylmethadol and its principal metabolites in man. Journal of Analytical Toxicology. 1982;6:100-105.
Fraser, A.D. Clinical toxicology of drugs used in the treatment of opiate dependency. Clinics in Laboratory Medicine. 1990;10:375-386.
Fraser, H.F., Gorodetzky, C.W., Kay, D.C., Yeh, S.Y. Possible influence of opioid normetabolites on the onset, magnitude and quality of the opioid abstinence syndrome. Drug and Alcohol Dependence. 1980;5:255-272.
Fraser, H.F., Isbell, H. Actions and addiction liabilities of alpha-acetylmethadol in man. Journal of Pharmacology and Experimental Therapy. 1952.
Freedman, R.R., Czertko, G. A comparison of thrice weekly LAAM and daily methadone in employed heroic addicts. Drug and Alcohol Dependence. 1981;8:215-222.
Goldstein, A. A clinical experience with LAAM. In: Rx: 3x/Week LAAM: Alternative to Methadone. Rockville, Maryland: National Institute of Drug Abuse; 1976: 115-117. US Department of Health, Education, and Welfare publication ADM 76-347. NIDA Research Monograph 8.
Goldstein, A. On the role of chemotherapy in the treatment of heroin addiction. American Journal of Drug and Alcohol Abuse. 1975;2:279-288.
Goldstein, A., Judson, B. Three critical issues in the management of methadone programs: critical issue 3: can the community be protected against the hazards of take-home methadone? In: Bourne, P.G., ed. Addiction. New York, New York: Academic Press; 1974: 140-148.
Gorski, T.T. Managed care: a guide to survival. Addiction and Recovery. 1993.
Grevert, P., Masover, B., Goldstein, A. Failure of methadone and levomethadyl acetate (levo-alpha-acetylmethadol, LAAM) maintenance to affect memory. Archives of General Psychiatry. 1977;34:849-853.
Hargreaves, W.A., Ling, W., Brown, T.C., et al. Women on LAAM maintenance: initial experiences. Journal of Psychedelic Drugs. 1979;11:223-229.
Hargreaves, W.A., Tyler, J, Weinberg, J.A., Sorensen, J.L., Benowitz, N. (-)-Alpha-acetylmethadol effects on alcohol and diazepam use, sexual function and cardiac function. Drug and Alcohol Dependence. 1983;12:323-332.
Henderson, G.L., Wilson, B.K., Lau, D.H. Plasma 1-alpha-acetylmethadol (LAAM) after acute and chronic administration. Clinical Pharmacology and Therapeutics. 1977;21:16-25.
Ho, A.K., Chen, R.C. Interactions of narcotics, narcotic antagonists, and ethanol during acute, chronic, and withdrawal states. Annals of the New York Academy of Sciences. 1976;281:297-310.
Institute of Medicine. Federal Regulation of Methadone Treatment. Washington, DC: National Academy Press. 1995.
Inturrisi, C.E. Disposition of narcotics and narcotic antagonists. Annals of the New York Academy of Sciences. 1976;281:273-287.
Jaffe, J.H., Schuster, C.R., Smith, B.B., Blackly, P.H. Comparison of acetylmethadol and methadone in the treatment of long-term heroin users: a pilot study. In: Rx: 3x/Week LAAM: Alternative to Methadone. Rockville, Maryland: National Institute of Drug Abuse; 1976: 72-73. US Department of Health, Education, and Welfare publication ADM 76-347. NIDA Research Monograph 8.
Jaffe, J.H., Senay, E.C. Methadone and l-methadyl acetate. Use in management of narcotic addicts. Journal of the American Medical Association. 1971;216:1303-1305.
Jaffe, J.H., Senay, E.C., Schuster, C.R., et al. Methadyl acetate vs. methadone: a double-blind study in heroin users. Journal of the American Medical Association. 1972;222:437-442.
Jakubovic, A. Degradation of met-enkephalin by extracts of various regions of the human brain: effects of antipsychotics and narcotics in vitro. Peptides. 1982;3:21-26.
Jasinski, D.R. Recent developments in chemotherapy of narcotic addiction. Part VI. LAAM and narcotic antagonists: introductory remarks. Annals of the New York Academy of Sciences. 1978;311:197-198.
Judson, B.A., Carney, T.M., Goldstein, A. Naltrexone treatment of heroin addiction: efficacy and safety in a double-blind dosage comparison. Drug and Alcohol Dependence. 1981;7:325-346.
Judson, B.A., Goldstein, A. Episodes of heroin use during maintenance treatment with stable dosage of (-)-alpha-acetylmethadol (methadol acetate, LAAM). Drug and Alcohol Dependence. 1983;11:271-278.
Judson, B.A., Goldstein, A. Levo-alpha-acetylmethadol (LAAM) in the treatment of heroin addicts. I. Dosage schedule for induction and stabilization. Drug and Alcohol Dependence. 1979;4:461-466.
Judson, B.A., Goldstein, A. Naltrexone treatment of heroin addiction: one-year follow-up. Drug and Alcohol Dependence.
Judson, B.A., Goldstein, A. Symptom complaints of patients maintained on methadone, LAAM (methadyl acetate) and naltrexone at different times in their addiction careers. Drug and Alcohol Dependence. 1982;10:269-282.
Judson, B.A., Goldstein, A., Inturrisi, C.E. Methadyl acetate (LAAM) in the treatment of heroin addicts. II. Double-blind comparison of gradual and abrupt detoxification. Archives of General Psychiatry. 1983;40:834-840.
Judson, B.A., Himmelberger, D.U., Goldstein, A. The naloxone test for opiate dependence. Clinical and Pharmocologic Therapeutics. 1980;27:492-501.
Kaiko, R.F., Inturrisi, C.E. Disposition of acetyl-methodol in relation to pharmacologic action. Clinical Pharmacology and Therapeutics. 1975;18:96-103.
Karp-Gelernter, E., Savage, C., McCabe, O.L. Evaluation of clinic attendance schedules for LAAM and methadone: a controlled study. International Journal of the Addictions. 1982;17:805-813.
Karp-Gelernter, E., Wurmser, L., Savage, C. Therapeutic effects of methadone and 1-alpha-acetylmethodol. American Journal of Psychiatry. 1976;133:955-957.
Keats, A.S., Beecher, H.K. Analgesic activity and toxic effects of acetylmethadol isomers in man. Journal of Pharmacology and Experimental Therapy. 1952;105:210-215.
Klett, C.J. The SAODAP cooperative studies of LAAM: unblinded comparison with methadone. In: The International Challenge of Drug Abuse. Rockville, Maryland: National Institute of Drug Abuse; 1978: 271-276. US Department of Health, Education, and Welfare publication ADM 78-654. NIDA Research Monograph 19.
Leimbach, D.G., Eddy, N.B. Synthetic analgesics: III. Methadols, isomethadols and their acyl derivatives. Journal of Pharmacology and Experimental Therapy.
Ling, W. Levo-alpha-acetylmethadol (LAAM) for opiate addiction. Current Psychiatric Therapies. 1978;18:173-180.
Ling, W. Levo-alpha-acetylmethadol: new drug for old habits. In: The International Challenge of Drug Abuse. Rockville, Maryland: National Institute of Drug Abuse; 1978: 242-248. US Department of Health, Education, and Welfare publication ADM 78-654. NIDA Research Monograph 19.
Ling, W., Blakis, M., Holmes, E.D., et al. Restabilization with methadone after methadyl acetate maintenance. Archives of General Psychiatry. 1980;37:194-196.
Ling, W., Charuvastra, C., Kaim, S.C., Klett, C.J. Methadyl acetate and methadone as maintenance treatments for heroin addicts. A Veterans Administration cooperative study. Archives of General Psychiatry.
Ling, W., Charuvastra, V.C., Klett, C.J. Current status of the evaluation of LAAM as a maintenance drug for heroin addicts. American Journal of Drug and Alcohol Abuse. 1975;2:307-315.
Ling, W., Dorus, W., Hargreaves, W.A., et al. Alternative induction and crossover schedules for methadyl acetate. Archives of General Psychiatry. 1984;4:193-199.
Ling, W., Klett, C. J., Gillis, R.D. A cooperative clinical study of methadyl acetate. I. Three-times-a-week regimen. Archives of General Psychiatry. 1978;35:345-353.
Lopez, F. Confidentiality of Patient Records for Alcohol and Other Drug Treatment. Technical Assistance Publication Series 13. Rockville, Maryland: Center for Substance Abuse Treatment; 1994. US Department of Health and Human Services publication SMA 95-3018.
Marcovici, M., O'Brien, C.P., McLellan, A.T., Kacian, J. A clinical controlled study of l-alpha-acetylmethadol in the treatment of narcotic addiction. American Journal of Psychiatry. 1981;138:234-236.
Massey, W.J. The "step-down" model of chemical dependency treatment. Addiction and Recovery. 1993.
Matsuyama, S.S., Charuvastra, V.C., Jarvik, L.F., et al. Chromosomes in patients receiving methadone and methadyl acetate. Archives of General Psychiatry. 1978;35:989-991.
Matsuyama, S.S., Charuvastra, V.C., Ouren, J., Schwartz, J., Jarvik, L. Immunoglobulin levels in heroin addicts after treatment with methadone and methadyl acetate. Drug and Alcohol Dependence. 1980;6:345-348.
McLellan, A.T., Alterman, A.I., Cacciola, J., Metzger, D.S., O'Brien, C.P. A new measure of substance abuse treatment. Initial studies of the treatment services review. Journal of Nervous and Mental Disease. 1992;180:101-110.
McLellan, A.T., Durell, J. Outcome evaluation in psychiatric and substance abuse treatments: concepts, rationale and methods. Submitted for publication. 1995.
McLellan, A.T., Luborsky, L., O'Brien, C.P., Woody, G.E. An improved diagnostic instrument for substance abuse patients: the Addiction Severity Index. Journal of Nervous and Mental Disease. 1980;168:26-33.
McLellan, A.T., Parikh, G., Braff, A., et al. Addiction Severity Index, Administration Manual, 5th ed. Philadelphia: Pennsylvania Veterans' Administration Center for Studies of Addiction. 1990.
McMillan, D.E. Effects of N-substituted analogs of (-) -a- acetylmethadol and (-) -a- methadol on schedule controlled behavior. Drug Development Research. 1982;2:419-425.
Mendelson, J.H., Inturrisi, C.E., Renault, P., Senay, E.C. Effects of acetylmethadol on plasma testosterone. Clinical Pharmacology and Therapeutics. 1976;19:371-374.
Misra, A.L., Mule, S.J. L-alpha-acetylmethadol (LAAM) pharmacokinetics and metabolism: current status. American Journal of Drug and Alcohol Abuse. 1975;2:301-305.
Moolchan, E.T., Hoffman, J.A. Phases of treatment: a practical approach to methadone maintenance treatment. International Journal of the Addictions. 1994;29:135-160.
National Institute on Drug Abuse, Medications Development Division. Information on LAAM: Chemistry, Pharmacology and Clinical Trial Results. Rockville, Maryland: National Institute on Drug Abuse. 1993.
Newmann, M.C., Klett, J.C, Stillman, R. Implementing a national study of a new maintenance drug. American Journal of Drug and Alcohol Abuse. 1975;2:289-300.
On the LAAM: new drug for opiate addiction. State ADM Report. 1993;;July/August: 3.
[no authors listed]. ORLAAM: levo methadyl acetate hydrochloride oral solution for the management of opiate dependence: information for physicians. Columbus, Ohio: Roxane Laboratories, Inc., no date.
Parwatikar, S., Crawford, J., Unverdi, C. LAAM (l-a-acetylmethadol) study in St. Louis. American Journal of Drug and Alcohol Abuse. 1975;2:341-352.
Payte, T. Unpublished study. 1992.
Peck, R.L. Addictions treatment: where it's headed. Addiction and Recovery. 1993;November:14-17.
Preston, K.L., Bigelow, G.E. Pharmacological advances in addiction treatment. International Journal of the Addictions. 1985;20:845-867.
Rapp, R.C., Siegal, H.A., Fisher, J.H., et al. A "strengths-based" approach to enhance treatment compliance. Addiction and Recovery. 1993;November:22-25.
Rawson, R.A., Ling, W. Levo-alpha-acetylmethadol (LAAM) for the Treatment of Opiate Dependence: A White Paper. Prepared for the California Office of Alcohol and Drug Programs. 1993.
Renault, P.F. The future of LAAM. In: The International Challenge of Drug Abuse. Rockville, Maryland: National Institute of Drug Abuse. 1978: 291-293. US Department of Health, Education, and Welfare publication ADM 78-654. NIDA Research Monograph 19.
Resnick, R. Problems of methadone diversion and implications for control. International Journal of the Addictions. 1977;12:803-805.
Rounsaville, B.J., Tims, F.M., Horton, A.M. Jr., Sowder, B.J. Diagnostic Source Book on Drug Abuse Treatment and Research. Rockville, Maryland: National Institute on Drug Abuse; 1993. US Department of Health and Human Services publication NIH 93-3508.
Savage, C., Karp, E., Curran, S. A methadone/(1)-alpha acetylmethadol (LAAM) maintenance study [proceedings]. In: Rx: 3x/Week LAAM: Alternative to Methadone. Rockville, Maryland: National Institute of Drug Abuse; 1976: 86-87. US Department of Health, Education, and Welfare publication ADM 76-347. NIDA Research Monograph 8.
Savage, C., Karp, E.G., Curran, S.F., Hanlon, T.E., McCabe, O.L. Methadone/LAAM maintenance: a comparison study. Comprehensive Psychiatry. 1976;17:415-424.
Schecter, A., Kauders, F. Patient deaths in a narcotic antagonist (naltrexone) and l-alpha-acetylmethadol program. American Journal of Drug and Alcohol Abuse. 1975;2:443-449.
Segal, R., Everson, A., Sellers, E.M., Thakur, R. Failure of acetylmethadol in treatment of narcotic addicts due to nonpharmacologic factors. CMA Journal. 1976;115:1014-1016.
Senay, E.C. Methadone maintenance treatment. International Journal of the Addictions. 1985;20:803-821.
Senay, E.C., Dorus, W., Renault, P.F. Methadyl acetate and methadone. An open comparison. Journal of the American Medical Association. 1977;237:138-142.
Senay, E.C., Jaffe, J.H., DiMenza, S., Renault, P.F. A 48-week study of methadone, methadyl acetate, and minimal services. In: Fisher, S., and Freedman, A.M., eds. Opiate Addiction: Origins & Treatment. New York: Halsted; 1974.
Senay, E.C., Renault, P.F., DiMenza, S., et al. Three times a week LAAM equals seven times a week methadone: a preliminary report of a controlled study. In: Senay, E., Shorty, V., and Alksne, H., eds. Developments in the Field of Drug Abuse: Proceedings. Cambridge, Massachusetts: Shenkman; 1975.
Serban, G. New approach to the rehabilitation of the hard core drug addict (heroin methadone addicts) a pilot community study. Journal of Clinical Psychiatry. 1978;39:111-116.
Silverman, K., Schuster, C.R., Brooner, R.K., Montoya, I.D., Preston, K.L. Contingency management of cocaine use in a methadone maintenance program. Paper presented at the annual meeting of the Association for the Advancement of Behavior Therapy. Atlanta, Georgia. 1993.
Sorensen, J.L., Hargreaves, W.A., Weinberg, J.A. Heroin addict responses to six weeks of detoxification with LAAM. Drug and Alcohol Dependence. 1982;9:79-87.
Sorensen, J.L., Hargreaves, W.A., Weinberg, J.A. Withdrawal from heroin in three or six weeks: comparison of LAAM versus methadone. Archives of General Psychiatry. 1982;39:167-171.
Swanson, D.A. Pharmacotherapy of opiate addiction. South African Medical Journal. 1976;50:857-859.
Tennant, F.S. Jr., Rawson, R.A., Pumphrey, E., Seecof, R. Clinical experiences with 959 opioid-dependent patients treated with levo-alpha-acetylmethadol (LAAM). Journal of Substance Abuse Treatment. 1986;3:195-202.
Thomas, D.B., Whysner, J.A., Newmann, M.C. The phase III clinical evaluation of LAAM: I. Comparative epidemiology of mortality in LAAM and methadone. In: Problems of Drug Dependence. Rockville, Maryland: National Institute of Drug Abuse; 1979: 289-295b. NIDA Research Monograph 27.
Toro-Goyco, E. Binding of l-alpha-acetymethadol and its metabolites to blood constituents. Biochemical Pharmacology. 1980;29:1897-1902.
Wilson, B.K., Spannagel, V., Thomson, C.P. The use of l-alpha-acetylmethadol in treatment of heroin addiction: an open study. International Journal of the Addictions. 1976;11 1091-1100.
Whysner, J.A. Phase III clinical study of levo-alpha-acetylmethadol. In: International Challege of Drug Abuse. Rockville, Maryland: National Institute of Drug Abuse; 1978; 109-111. US Department of Health, Education, and Welfare publication ADM 78-654. NIDA Research Monograph 19.
Wolven, A., Archer, S. Toxicology of LAAM. In: Rx: 3x/Week LAAM: Alternative to Methadone. Rockville, Maryland: National Institute of Drug Abuse, 1976; 29-38. US Department of Health, Education, and Welfare publication ADM 76-347. Research Monograph 8.
Young, N.K. Invest in Treatment for Alcohol and Other Drug Problems: It Pays. Washington, D.C.: National Association of State Alcohol and Drug Abuse Directors. 1994.
Zaks, A., Fink, M., Freedman, A.M. Levomethadyl in maintenance treatment of opiate dependence. Journal of the American Medical Association. 1972;220:811-813.
Zangwell, B.C., McGahan, P., Dorozynsky, L., McLellan, A.T. How effective is LAAM treatment? Clinical comparison with methadone. In: Harris, L.S., ed. Problems of Drug Dependence: Proceedings of the 47th Annual Scientific Meeting, the Committee on Problems of Drug Dependence, Inc. Rockville, Maryland: National Institute on Drug Abuse; 1986: 249-255. NIDA Research Monograph 67.
Zweben, J.E., Payte, J.T. Methadone maintenance in the treatment of opioid dependence. A current perspective. Western Journal of Medicine. 1990.

### Other Authorities

Drugs Used for Treatment of Narcotic Addicts, 21 C.F.R. Part 291 Section 291. 505 (1993), 201.57 (1994).