# Consensus Panel

Co-Chairs
- The Honorable Michael W. McPhail
- County and Youth Court Judge
- Forrest County Court
- Hattiesburg, Mississippi
- Barbara McNulty Wiest, M.A.
- Program Supervisor
- Youth Alcohol and Drug Treatment and Prevention Programs
- Clackamas County Mental Health Center
- Marylhurst, Oregon

Facilitators
- Xavier I. Cortada, J.D.
- Adjunct Assistant Professor, Center for Family Studies
- University of Miami
- School of Medicine
- Miami, Florida
- Larry LeFlore, Ph.D.
- Professor
- Institute of Juvenile Justice Administration and Delinquency Prevention
- Department of Criminal Justice
- The University of Southern Mississippi
- Hattiesburg, Mississippi
- Vicki J. Sandage, J.D.
- Administrator
- Pulaski County Juvenile Services
- Little Rock, Arkansas

Workgroup Members
- Ellen Fabian Brokofsky, C.A.D.A.C.
- Chief Probation Officer
- District #19 Probation
- Papillion, Nebraska
- John P. Delaney, Jr., J.D.
- Deputy District Attorney
- Office of the District Attorney
- Philadelphia, Pennsylvania
- Wiley A. Griffin, Jr.
- President and CEO
- Newark Renaissance House, Inc.
- Newark, New Jersey
- Pamela Y. Harrell, M.Ed.
- Special Programs Coordinator
- Oklahoma County District Attorney's Office
- Oklahoma City, Oklahoma
- Cecilia E. Mascarenas
- Probation Supervisor II
- Denver Juvenile Justice Integrated T.A.S.C. Coordinator
- Denver Juvenile Court
- Denver, Colorado
- Patricia Spaniol Mathews, M.A.
- Juvenile Justice Coordinator
- Substance Abuse Programs
- Alcohol, Drug Abuse and Mental Health Program Office
- Department of Health and Rehabilitation Services
- Tallahassee, Florida
- M. Kim Oh, M.D.
- Associate Professor, Department of Pediatrics
- Division of Adolescent Medicine
- University of Alabama at Birmingham
- School of Medicine
- Birmingham, Alabama
- Maria Felisa Ramiu, J.D.
- Staff Attorney
- Youth Law Center
- San Francisco, California
- The Honorable Linda Stout Saunders
- Acting Justice
- Concord District Court (Concord, N.H.)
- Hopkinton, New Hampshire
- Celeste Whitewolf, J.D.
- Attorney at Law
- Whitewolf Law Office
- Portland, Oregon