# Appendix I—Federal Resource Panel

- Sandra M. Clunies, M.S., N.C.A.D.C.
- Government Project Officer, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Melanie Duckworth, M.S.W.
- Health Education Specialist, Division of Adolescent and School Health
- Centers for Disease Control and Prevention
- Atlanta, Georgia
- Bennett Fletcher, Ph.D
- Senior Research Psychologist, Services Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland
- Ingrid D. Goldstrom, M.Sc.
- Social Science Analyst, Statistical Research Branch
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- John McGovern
- Public Health Analyst, Division of Healthy Start
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Rockville, Maryland
- Roberta Messalle
- Public Health Analyst, Office of Policy Coordination
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Vincent M. Picciano, M.A.
- Director of Court Services
- Juvenile and Domestic Relations District Court
- Nineteenth Judicial District
- Fairfax County
- Fairfax, Virginia
- Carol Rest-Mincberg, M.P.H.
- Public Health Advisor, Treatment Operations and Review Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Barbara T. Roberts, Ph.D.
- Senior Policy Analyst
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.
- Marilyn McCoy Roberts
- Senior Policy Analyst
- National Center for State Courts
- Arlington, Virginia
- Mark I. Soler. J.D.
- Executive Director
- Youth Law Center
- San Francisco, California
- Barbara McNulty Wiest, M.A. -- Co-Chair
- Program Supervisor, Youth Alcohol and Drug
- Treatment and Prevention Programs
- Clackamas County Mental Health Center
- Marylhurst, Oregon