# Appendix C—CSAT Juvenile Justice Treatment Planning Chart

The Juvenile Justice Treatment Planning Chart is a 3 1/2 foot fold-out chart suitable for display. The reverse side of the chart contains a glossary of the terms used in the chart. There was no effective way to present this chart in electronic format.

Both a hard copy of the chart printed on glossy paper and a copy of the entire TIP containing the chart can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for the chart by itself is PHD 598 and for the entire TIP is BKD169. The documents are free and can be ordered from NCADI's electronic catalog athttp://www.health.org/pubs/catalog/ordering.htm or by calling 1-800-729-6686.