# Appendix J—Field Reviewers

- Robert E. Anderson
- Director, Quality Assurance and Case Management Programs
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.
- Robert B. Aukerman, M.S.W.
- Director, Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado
- Robert C. Beals, M.C.J.A.
- Youth Services Technical Assistant
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas
- Patricia A. Belmont, M.A.
- Youth Treatment Coordinator, Division of Addiction Services
- New Jersey Department of Health
- Trenton, New Jersey
- Stephen P. Bogan, M.A., N.C.A.C. II
- Youth Treatment Specialist, Family and Prevention Section
- Division of Alcohol and Substance Abuse
- Department of Social and Health Services
- Olympia, Washington
- John R. Boker, Ph.D.
- Assistant Dean, Academic and Faculty Affairs
- University of Tennessee-Memphis
- College of Medicine
- Memphis, Tennessee
- Ellen Fabian Brokofsky, C.A.D.A.C.
- Chief Probation Officer
- District #5 Probation
- Papillion, Nebraska
- Robert Burke
- Senior Attorney, Defender Division
- National Legal Aid and Defenders Association
- Washington, D.C.
- Carmen Carrillo
- Executive Director
- Urban Children's Mental Health Coalition
- Denver, Colorado
- Betty J. Clark, Esquire
- Criminal Defense Attorney
- District of Columbia
- Washington, D.C.
- Deborah C. Cleckley, R.N., M.S.N.
- Director, Quality Assurance and Education
- Jefferson County Department of Health
- Birmingham, Alabama
- Xavier I. Cortada, M.P.A., J.D.
- Adjunct Assistant Professor of Psychiatry
- Center for Family Studies
- University of Miami School of Medicine
- Miami, Florida
- John P. Delaney, Jr., J.D.
- Deputy District Attorney
- Office of the District Attorney
- Philadelphia, Pennsylvania
- Richard Dembo, Ph.D.
- Professor of Criminology
- Department of Criminology
- University of South Florida
- Tampa, Florida
- David D. Dillingham, M.S.W.
- Correctional Program Specialist
- National Institute of Corrections
- Washington, D.C.
- A.M. Dominguez, Jr., Esquire
- District Attorney, 19th Judicial District
- State of Colorado
- Greeley, Colorado
- Dwane Durant, M.A.
- Director, Alcoholism and Drug Services Center
- Volunteers of America
- San Diego, California
- Janice Embree-Bever, M.A., C.A.C. III
- Grants Management Officer III
- Adolescent Specialist, Alcohol and Drug Abuse Division
- Office of Health and Rehabilitation
- Colorado Department of Human Services
- Denver, Colorado
- Janice Gabe, M.S.W., C.C.S.W., N.C.A.C. II
- President
- New Perspectives
- Indianapolis, Indiana
- Ingrid D. Goldstrom, M.Sc.
- Social Science Analyst, Statistical Research Branch
- Center for Mental Health Services
- Rockville, Maryland
- Wiley A. Griffin, Jr.
- President and CEO
- Newark Renaissance House, Inc.
- Newark, New Jersey
- Pamela Y. Harrell, M.Ed.
- Special Programs Coordinator
- Oklahoma County District Attorney's Office
- Oklahoma City, Oklahoma
- Kenneth J. Hoffman, M.D., M.P.H.
- Director, Center for Training and Education in Addiction Medicine
- Department of Preventive Medicine and Biometrics
- Uniformed Services University of the Health Sciences
- Bethesda, Maryland
- Steven L. Jaffe, M.D.
- Associate Professor of Psychiatry
- Emory University and Clinical Professor of Psychiatry
- Morehouse School of Medicine
- Atlanta, Georgia
- Randy Jones
- Regional Coordinator, Alabama Department of Youth Services
- Community and Regional Services Division
- Birmingham, Alabama
- Linda Kaplan, M.A., C.A.E.
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors (NAADAC)
- Arlington, Virginia
- Joseph B. Kelly, M.A., L.P.C., C.A.C.
- Counselor and Therapist
- Bay Area Counseling
- Traverse City, Michigan
- Larry LeFlore, Ph.D.
- Professor, Department of Criminal Justice
- Institute of Juvenile Justice
- Administration and Delinquency Prevention
- The University of Southern Mississippi
- Hattiesburg, Mississippi
- David W. Lloyd, J.D.
- Director, National Center on Child Abuse and Neglect
- Administration on Children, Youth and Families
- Administration for Children and Families
- U.S. Department of Health and Human Services
- Washington, D.C.
- Patricia Marrone
- Executive Director
- The Center: Counseling, Education and Crisis Services
- Pleasanton, California
- Cecilia E. Mascarenas
- Probation Supervisor II
- Coordinator, Denver Juvenile Justice Integrated, T.A.S.C.
- Denver Juvenile Court
- Denver, Colorado
- Patricia Spaniol Mathews, M.A.
- Adolescent Treatment Coordinator, Substance Abuse Programs
- Alcohol, Drug Abuse and Mental Health Program Office
- Department of Health and Rehabilitation Services
- Tallahassee, Florida
- Mary J. McGuire, Esquire
- Prosecutor, Division for Children, Youth and Families
- State of New Hampshire
- Nashua, New Hampshire
- Kenneth McLaughlin
- Director, Central Intake
- Fairfax County Juvenile District Court
- Fairfax, Virginia
- Cheryl D. McMichael, M.A.
- Manager, School Intervention Program
- South Carolina Department of Alcohol and Other Drug Abuse Services
- Columbia, South Carolina
- Roberta Messalle
- Public Health Analyst, Office of Policy Coordination
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Donald T. Nichols, M.S.M., C.A.D.A.C., N.C.A.C. II
- Executive Director
- Pathways of Casa Grande
- Casa Grande, Arizona
- M. Kim Oh, M.D.
- Associate Professor, Department of Pediatrics
- Division of Adolescent Medicine
- University of Alabama at Birmingham
- Birmingham, Alabama
- Anlee D. Olson
- Addictions Program Specialist, Open Door
- Substance Abuse Treatment Program
- Anne Arundel County Department of Health
- Annapolis, Maryland
- Kerry J. O'Neil
- Chief of Offender Services
- Rhode Island Department of Substance Abuse
- Cranston, Rhode Island
- Donald A. Paoletti, M.D.
- Assistant Professor, Division of Child/Adolescent Services
- Department of Psychiatry
- University of Alabama at Birmingham
- Birmingham, Alabama
- Mary Parthemer, M.S.W., L.C.S.W.
- Program/Clinical Director
- Looking Glass Adolescent Recovery Program
- Eugene, Oregon
- Carolyn M. Peake, M.P.A.
- Social Science Analyst, Office of Communication and Research Utilization
- National Institute of Justice
- Washington, D.C.
- Robert O. Phillips, M.A., N.C.A.C. II.
- Clinical Therapist
- Counseling Associates, Inc.
- Roswell, New Mexico
- Vincent M. Picciano, M.A.
- Director of Court Services
- Juvenile and Domestic Relations District Court
- Nineteenth Judicial District
- Fairfax County
- Fairfax, Virginia
- James D. Platt, M.A., C.A.D.C., N.C.C., C.E.A.P.
- Instructor of Psychiatry
- Dartmouth-Hitchcock Medical Center
- Dartmouth Medical School (Psychiatry)
- Lebanon, New Hampshire
- Maria Felisa Ramiu, J.D.
- Staff Attorney
- Youth Law Center
- San Francisco, California
- Scott M. Reiner, M.S., C.A.C.
- Substance Abuse Program Supervisor
- Virginia Department of Youth and Family Services
- Richmond, Virginia
- Marilyn McCoy Roberts
- Senior Policy Analyst
- National Center for State Courts
- Arlington, Virginia
- Bettie S. Ross
- Executive Director, DREAM of Hattiesburg, Inc.
- Drug-free Resources for Education and Alternatives in Mississippi
- Hattiesburg, Mississippi
- JoAnn Samson, Ph.D., J.D.
- Toxicologist/Attorney
- Concord, New Hampshire
- Vicki J. Sandage, J.D.
- Assistant Attorney General
- Outreach Division
- Office of the Attorney General
- Little Rock, Arkansas
- Gus Sandstrom, Jr., Esquire
- District Attorney
- Colorado 10th Judicial District
- Pueblo, Colorado
- Linda Stout Saunders, J.D.
- Director
- Jurimetrics Associates
- Hopkinton, New Hampshire
- Steven J. Shapiro
- Public Health Advisor, Criminal Justice Systems Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Marsha Sturdevant, M.D.
- Assistant Professor, Department of Pediatrics
- Division of Adolescent Medicine
- University of Alabama at Birmingham
- Birmingham, Alabama
- Jose Szapocznik, Ph.D.
- Professor and Director, Center for Family Studies
- University of Miami School of Medicine
- Department of Psychistry and Behavioral Sciences
- Miami, Florida
- Michael Torch, M.A., C.A.D.C.
- Senior Director of Operations
- Seaborne Hospital
- Dover, New Hampshire
- Stephen Trujillo
- Director, AIDS Outreach and Education
- CODAC Behavioral Health Services
- Tucson, Arizona
- Donald G. Williams, Ph.D.
- Professor of Sociology
- Department of Sociology
- Grand Valley State University
- Allendale, Michigan
- Elaine Wilson, A.C.S.W., M.P.H.
- Chief, Alcohol and Drug Abuse Division
- Hawaii Department of Health
- Honolulu, Hawaii
- Raymond E. Wilson, C.A.D.C., N.C.A.C. II
- AOD Adolescent Clinical Specialist
- Drug Treatment Programs
- Marion County Health Department
- Salem, Oregon
- Joyce L. Wright, Esquire
- Division Chief, Juvenile Courts Division
- Office of the State's Attorney for Baltimore City
- Baltimore, Maryland
- John K. Zachariah
- Deputy Court Administrator
- Cuyahoga County Juvenile Court
- Cleveland, Ohio