# Appendix A -- Bibliography

Alcohol, Drug Abuse, and Mental Health Administration. Report of the Secretary's Task Force on Youth Suicide. Rockville, Maryland: U.S. Department of Health and Human Services, Public Health Service. 1992.
Allen-Hagen, B., Sickmund, M. Juveniles and Violence: Juvenile Offending and Victimization. Washington, D.C.: Office of Juvenile Justice and Delinquency Prevention. 1993.
Altschuler, D.M., Armstrong, T.L. Intensive Community-Based Aftercare Programs: Assessment Report. Washington, D.C.: Office of Juvenile Justice and Delinquency Prevention. 1990.
American Society of Addiction Medicine Committee of Practice Guidelines. The Role of Phenytoin in the Management of Alcohol Withdrawal Syndrome. Washington, D.C.: American Society of Addiction Medicine. 1994.
Baird, C., Storrs, G., Connely, H. Classification of Juveniles in Correction: A Model Systems Approach. Washington, D.C.: Arthur D. Little, Inc. 1984.
Bazemore, G. On mission statements and reform in juvenile justice: the case of the balanced approach. Federal Probation. 1992;.
Bazemore, G.T. The Balanced Approach: Restorative Justice for Juvenile Offenders. An Overview of a New OJJDP Initiative. Fort Lauderdale, Florida: Florida Atlantic University. 1992a.
Bureau of Justice Assistance. Accountability in Dispositions for Juvenile Drug Offenders. 1992.
Center for Substance Abuse Treatment. Guidelines for the Treatment of Alcohol- and Other Drug-Abusing Adolescents. Rockville, Maryland: U.S. Department of Health and Human Services; 1993. DHHS publication no. (SMA) 93-2010. Treatment Improvement Protocol (TIP) Series 4.
Center for Substance Abuse Treatment. Pregnant, Substance-Using Women. Rockville, Maryland: U.S. Department of Health and Human Services; 1993. DHHS publication no. (SMA) 93-1998. Treatment Improvement Protocol (TIP) Series 2.
Center for Substance Abuse Treatment. Screening and Assessment of Alcohol- and Other Drug-Abusing Adolescents. Rockville, Maryland: U.S. Department of Health and Human Services; 1993. DHHS publication no. (SMA) 93-2009. Treatment Improvement Protocol (TIP) Series 3.
Chaiken, M.R., Johnson, B.D. Characteristics of Different Types of Drug-Involved Offenders. Washington, D.C.: Office of Communication and Research Utilization, U.S. Department of Justice, National Institute of Justice. 1988.
Dembo, R., Schmeidler, J., Williams, L., et al. Recidivism among high-risk youths: study of a cohort of juvenile detainees. International Journal of the Addictions. 1991;;26:121-177.
Farrow, F., Brunner, C. Getting to the Bottom Line: State and Community Strategies for Financing Comprehensive Community Service Systems. Falls Church, Virginia: National Center for Service Integration. 1993.
Feinleib, M.R. Report of the Secretary's Task Force on Youth Suicide. Rockville, Maryland: Public Health Service, Alcohol, Drug Abuse, and Mental Health Administration. 1989.
Galanter, M., Kleber, H.D. Textbook of Substance Abuse Treatment. Washington, D.C.: American Psychiatric Press. 1994.
Geismar, L.L., Wood, K.M. Family and Delinquency: Resocializing the Young Offender. New York, New York: Human Sciences Press, Inc. 1986.
Gerstein, D., Harwood, H.J. The effectiveness of treatment. In: Institute of Medicine, Treating Drug Problems, Volume 1. Washington, D.C.: National Academy Press. 1990;132-199.
Gerstein, D.R., Johnson, R.A., Harwood, H.J., et al. Evaluating Recovery Services: The California Drug and Alcohol Treatment Assessment (CALDATA). Sacramento, California: California Department of Alcohol and Drug Programs. 1994.
Hawkins, D., Catalano, R. Communities That Care: Risk-Focused Prevention Using the Social Development Strategy. Seattle: Developmental Research and Programs, Inc. 1994.
Klitzner, M.D., Rahdert, E. Screening and Assessing Adolescent Substance Abusers in Primary Care: The Adolescent Assessment Referral System. Rockville, Maryland: National Institute on Drug Abuse. 1992.
Lerner, K., Arling, G., Baird, S.C. Client management: classification strategies for case supervision. Crime and Delinquency. 1986;32:254-271.
Maloney, D., Romig, D., Armstrong, T. Juvenile probation: the balanced approach. Juvenile and Family Court Journal. 1988;.
National Council of Juvenile Family Court Judges' Alcohol and Substance Abuse Committee. Drugs-The American Family in Crisis: A Judicial Response (43 Recommendations); Revised 1994. Juvenile and Family Court Journal. 1994;46(1):114.
Navaline, H., Tucker, A., Metzger, D. Problem Severity Index. Philadelphia, Pennsylvania: Addiction Research and Treatment Center, Philadelphia Veterans Administration Medical Center. 1990.
Norfolk Interagency Consortium. Policies and Procedures Manual. Norfolk,Virginia: Norfolk Interagency Consortium. 1994.
Office of Juvenile Justice and Delinquency Prevention. Desktop Guide to Good Juvenile Probation Practice. Pittsburgh, Pennsylvania: National Center for Juvenile Justice. 1993.
Oh, M.A., Cloud, G.A., Wallace, L.S., et al. Sexual behavior and sexually transmitted diseases among male adolescents in detention. Sexually Transmitted Diseases. 1994;;21:127-132.
Rosenthal, R.S., Smith, J. Facts About Youth and Delinquency: A Citizen's Guide to Juvenile Justice. Washington, D.C.: National Institute for Juvenile Justice and Delinquency Prevention. 1982:;41.
Thomas, D.W. Summary Report: Substance Abuse Screening Protocol for the Juvenile Courts. Pittsburgh, Pennsylvania: National Center for Juvenile Justice. 1993.
U.S. Department of Justice. Characteristics of Different Types of Drug-Involved Defenders. Washington, D.C.: National Institute of Justice, Office of Communication and Research Utilization. 1988.
Young, N.K. Invest in Treatment For Alcohol and Other Drug Problems: It Pays. Washington, D.C.: National Association of State Alcohol and Drug Abuse Directors, Inc. 1994.

### Other Authorities

Confidentiality of Alcohol and Drug Abuse Patient Records, 42 C.F.R. Part 2.
Breed v. Jones,421 U.S. 519 (1975).
Fare v. Michael C.,442 U.S. 707 (1979).
In re Gault,387 U.S. 187 (1967).
Kent v. United States,383 U.S. 541 (1966).
McKeiver v. Pennsylvania,403 U.S. 528 (1971).
Schall v. Martin,467 U.S. 253 (1984).
Stanford v. Kentucky,492 U.S. 361 (1989).
Swisher v. Brady,438 U.S. 204 (1978).
Thompson v. Oklahoma,487 U.S. 815 (1988).
In re Winship,397 U.S. 385 (1970).