# Consensus Panel

Co-Chairs
- Janice Fay Kauffman, R.N., M.P.H., C.A.S.
- Director, Substance Abuse Treatment Services
- North Charles, Inc.
- Harvard Medical School
- Department of Psychiatry
- Cambridge Hospital and Associate Director
- Addictions Consultation and Education Team
- Division of Psychiatry
- Brigham and Women's Hospital
- Boston, Massachusetts
- George E. Woody, M.D.
- Chief, Substance Abuse Treatment Unit
- Veterans Affairs Medical Center and Clinical Professor
- Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania

Facilitators
- Barbara Brayton Espey, M.S.W., M.B.A.
- Deputy Director, Bureau of Substance Abuse Services
- Department of Public Health
- Commonwealth of Massachusetts
- Boston, Massachusetts
- Jeffrey A. Hoffman, Ph.D.
- Executive Director
- The Koba Institute
- Washington, D.C.
- Gwen Phillips, L.C.S.W.
- HIV Coordinator, Methadone Maintenance Program
- Veterans Affairs Medical Center
- Philadelphia, Pennsylvania
- John A. Renner, M.D., C.A.S.
- Associate Professor, Department of Psychiatry
- Boston University School of Medicine
- Veterans Affairs Outpatient Clinic
- Boston, Massachusetts

Workgroup Members
- Carol Addiss
- Administrator, Mental Health Services
- Riverside County Drug Abuse Program
- Riverside, California
- Robert K. Brooner, Ph.D.
- Director, Southeast Baltimore Center for Drug Abuse Treatment
- The Johns Hopkins Behavioral Biology Research Center
- Baltimore, Maryland
- Ward S. Condelli, Ph.D.
- Research Sociologist, Center for Social Research and Policy Analysis
- Research Triangle Institute
- Research Triangle Park, North Carolina
- James Herrera, M.A.
- Counselor III/Program Manager, Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico
- Alfonso D. Holliday, II, M.D., M.B.A.
- President/Medical Director
- Holliday Health Care, P.C.
- Gary, Indiana
- Michael L. Prendergast, Ph.D.
- Project Director, UCLA Drug Abuse Research Center
- UCLA Neuropsychiatric Institute
- Los Angeles, California
- Phyllis G. Reilly, M.A., C.A.D.C.
- Director, Addiction Recovery Services
- University of Medicine and Dentistry of
- New Jersey Community Mental Health Center at Piscataway
- Piscataway, New Jersey
- D. Dwayne Simpson, Ph.D.
- Director and Professor, Institute of Behavioral Research
- Texas Christian University
- Forth Worth, Texas
- Donald Storms, C.A.C., C.D.A.C.
- National Association of Alcoholism-Drug Abuse Counselors
- Hamden, Connecticut
- Richard Weisskopf
- Methadone Treatment Coordinator
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois
- Mark L. Willenbring, M.D.
- Associate Professor of Psychiatry
- University of Minnesota School of Medicine
- Minneapolis, Minnesota