# Chapter 3—Phases of Treatment

The concept of treatment phases can be useful in attempting to match patients and services. When treatment is conceptualized as occurring in phases, a patient can be regarded as engaging in a series of successive interventions within a single program, with each intervention building on the other and leading to one or more well-defined goals.

The concept of treatment phasing is by no means new to the field of alcohol and other drug (AOD) abuse treatment (Institute of Medicine, 1990a; 1990b); however, this approach has not been widely used in methadone programs (Kreek, 1991). Nevertheless, many methadone programs operate at least partially according to an informal phased model of treatment, and others often recognize the need to utilize phases in developing treatment plans. The value of having treatment phases within methadone programs has been recognized by Hoffman and Moolchan (1994), who have described a phased and highly structured treatment model. This chapter builds on and extends that model as one important aspect of an overall strategy for matching patients to treatment.

In this chapter, each phase of a six-phase treatment model is described. Key issues typically arising in each phase are discussed, along with indicators of patients' progress through each phase and strategies to facilitate their progress. The model is not linear; patients may encounter setbacks requiring return to an earlier treatment phase. Thus, indicators of lack of progress and strategies for addressing setbacks are discussed. A separate section addresses transitions between phases, discharge, and readmission. Two clinical issues -- hospitalization of patients and decisionmaking about take-home medications -- are also discussed.

## Scope of Treatment Phases

As shown in Exhibit 3-1 , treatment begins with the acute phase and progresses through the rehabilitation and supportive care phases. The model then branches out into three separate tracks according to the patient's progress. These tracks involve different types and intensities of treatment services that correspond to the patient's level of functioning. Patients who have achieved a high degree of stability but who continue to need methadone to maintain this level of stability enter the medical maintenance phase. Some patients may remain in this phase indefinitely. Others may be considered for methadone detoxification (medically supervised withdrawal), which is undertaken by reducing the dose over a period of weeks or months (tapering) under close supervision (Exhibit 3-1). Patients who complete tapering from methadone often enter a period of readjustment, and additional counseling may be needed to reinforce coping and relapse prevention skills. Finally, an aftercare phase in which patients maintain periodic contact with the program is often desirable.

Phases of Treatment Model for Methadone Treatment

The phased model is based on the assumption that although most patients will need long-term or lifetime methadone treatment, the type and intensity of services will vary throughout the course of treatment. This assumption is based on studies showing that most patients move between periods of remission and relapse to heroin use and that relapse is common, especially after they leave methadone treatment (Ball and Ross, 1991; Condelli and Dunteman, 1993; Dole and Joseph, 1978; Hubbard et al., 1989; Simpson et al., 1979).

Patients do not always move through all phases, and some move back and forth between phases at different times. Many patients who enter the Phases of Treatment rehabilitation phase relapse to uncontrolled use and reenter the acute phase. Such returns should be perceived not as a failure of either the program or the patient, but rather as a reflection of the addiction problem. For some, this pattern of stabilization and rehabilitation continues without progress to the medical maintenance phase. Some patients who have completed medically supervised withdrawal from ethadone may have to resume maintenance and supportive care.

To be most effective, phases of treatment should be established not as a fixed series of steps that are assigned specific timeframes, but rather as a dynamic continuum that allows each patient to progress according to his or her individual needs. Patients move through a particular phase gradually or rapidly, depending on a variety of biopsychosocial factors that are discussed in this and other chapters. Treatment outcomes should be evaluated not solely in terms of how many phases the patient has moved through, but rather by the degree to which the patient's needs, goals, and expectations have been met by the treatment program.

Although distinct treatment phases can be identified, it is important to emphasize that the services in any phase must also be appropriate not only to that phase but also to individual characteristics of the patient. These needs vary according to many factors, including age, sex, culture and ethnicity, education, and socioeconomic level. As described in Chapter 2, assessment of a patient's readiness for a particular phase, as well as assessment of his or her individual needs, should also occur on an ongoing basis (Simpson and Joe, 1993).

Finally, it should be noted that for many patients attendance at self-help groups such as Alcoholics Anonymous and Narcotics Anonymous, provides an important source of support and structure during all phases of treatment. Opioid substitution therapy programs should establish ties to local community groups and should encourage patients to attend.

## Acute Phase

The acute phase of treatment generally comprises the first days, weeks, or months of methadone maintenance. During this time, the patient is usually struggling to reduce illicit drug use and begins work to reduce the intensity of the psychiatric, medical, social, legal, family, and other problems that are associated with dependence. The most immediate aim during this phase is to achieve a methadone dosage level that suppresses withdrawal symptoms for 24 to 36 hours, does not produce sedation, and markedly reduces heroin use. A high intensity of services is typically needed during the acute phase of treatment, especially for patients with serious psychiatric, social, or medical problems.

In the following sections, important clinical issues to be addressed during the acute phase of treatment are discussed, strategies for addressing them are offered, and indicators for transition to the next phase are described. Exhibit 3-2 summarizes these discussions.

Exhibit 3-2 Acute Phase of Methadone Treatment: Clinical Issues, Strategies, and Issues for Transition to Rehabilitation Phase

Clinical Issues | Strategies to Address Issues | Indicators for Transition Into Rehabilitation Phase
Drug Use and Withdrawal; - Adequacy of methadone dose in suppressing withdrawal symptoms; - Continued use of opioids; - Use of alcohol and other illicit drugs | - Evaluate and communicate the need for dosage adjustments to adequate dosage (120-160 mg); - Accessible clinic hours; - Intensify treatment strategies; if no reduction in AOD use, refer to inpatient treatment; - Encourage attendance at self-help groups such as Alcoholics Anonymous and Narcotics Anonymous | - Elimination of opioid withdrawal signs, including drug craving; - Sense of well-being; - Ability to avoid situations that perpetuate continuing drug use; - Acknowledgement of addiction as problem and motivation to effect lifestyle changes
Medical and Psychiatric Problems; - Medical; - cavitary disease, pneumonia; hepatitis A,B,C,D; cellulitis; - Sickle cell; - Hemophilia; - Surgical; - Lung abscesses, skin replacement, renal failure; - Psychiatric illness; - Psychotic, anxiety, mood, and personality disorders; - High-risk behaviors | - Linkages to available resources, including medical/psychiatric and emergency services, between physician and hospital; - Ongoing counseling to reduce risk | - Stabilization of acute medical crises; - Ongoing established care for chronic conditions
Basic Needs; - Concerns over legal and financial issues; - Threats to personal safety; - Housing; - Transportation; - Lack of financial resources; - Childcare; - Pregnancy; - Advocacy | - Referrals to appropriate agencies; - Establish linkages and quick referral sources to obtain needed services; - Transportation arranged with other patients; - Maintain travel resources, including bus tokens and travel vouchers; - Identify legal advocate, eligibility case manager, or social worker to identify financial resources | - Provisions made for food, clothing, housing, and safety needs and financial assistance if necessary; - Relatively stable and secure living conditions; - Receives prenatal care; - Childcare resources established; - Transportation resources available
Therapeutic Relationship; - Establishing trust and feeling of support; - Myths surrounding methadone treatment (e.g., "Methadone gets into your bones.") | - Ensure that methadone dosage is adequate (60-120 mg); - Foster atmosphere of trust, familiarity (e.g., introduce patients to key staff members, encourage acquaintance with other patients); - Remain consistent yet flexible and readily available during acute situations; - Nonjudgmental attitude; - Address relationships (drug, lifestyle, etc.) that have negative influence on patient; - Provide incentives, stress benefits of treatment:; - Financial concerns; - Self-esteem and sense of well-being; - Freedom from drug cravings; - Minimize waiting times during scheduled appointments to demonstrate that the patient's time is valued; - Help create support system (e.g., encourage patient involvement in self-help, social, and recreational activities); - Dispel myths surrounding methadone treatment (include family as indicated) | - Regular attendance at group, individual, or (if indicated) family counseling; - Positive interaction with treatment providers; - Focus on appropriate range of treatment goals
Motivation/Patient Readiness; - Ambivalent attitudes about stopping illicit drugs; - Involuntary discharge; - Negative relationships with staff; - Introduction of methadone treatment without needed adjunctive support services; - Inadequate dosing; - Perception that methadone is a medication, not a means of social control; - Developing positive attitude for treatment | - Ensure that methadone dosage is adequate (60-120 mg); - Address ambivalence about giving up drugs, fears of making major life changes (Miller and Rollnick, 1991); - Stress benefits of methadone treatment:; - Preventing needle-borne infections; - Avoiding arrest and incarceration; - Peace of mind, relief of concerns over obtaining next fix; - Encourage patient to control his/her addiction | - Commitment to the treatment process; - Acknowledgement of addiction as a problem; - Beginning of changes in lifestyle and of addressing issues surrounding drug abuse

### Alcohol and Illicit Drug Use

One of the major goals of the acute phase is to eliminate opioid use as quickly as possible. This process involves

- Initially prescribing a methadone dose that will minimize the chances of sedation and other undesirable side effects
- Assessing the safety and adequacy of the dose
- Rapidly but safely increasing the dose to suppress acute withdrawal symptoms and discourage the patient from supplementing the methadone dosage with continued use of heroin.

As part of the stabilization process, it is critical for care providers to know what other drugs are being used. Most patients admitted to methadone programs have been using a variety of other substances, particularly cocaine and alcohol (Hubbard et al., 1989). Setting limits on other forms of illicit drug use and alcohol abuse is also a major goal of this phase. Urine screening should be conducted at least once a week. A recent study estimates that up to 75 percent of patients in methadone maintenance programs abuse cocaine (Avants et al., 1994). As described in Chapter 4, group and individual counseling for cocaine abusers is an important treatment element.

Many patients continue heavy alcohol use after they are admitted to methadone programs (Fairbank et al., 1993). In fact, many patients, as well as many alcohol users, do not consider alcohol to be a drug. Continued heavy use is often a serious problem for methadone patients, and it will markedly impair progress in treatment. Although it may not be realistic to totally eliminate alcohol use by all methadone patients, its consumption should be strongly discouraged, especially since it often serves as a trigger for moving on to the use of cocaine and ther illicit substances. Many programs use Breathalyzers to detect alcohol use and do not dispense methadone to intoxicated patients.

To be most effective, phases of treatment should be established not as a fixed series of steps that are assigned specific timeframes, but rather as a dynamic continuum that allows each patient to progress according to his or her individual needs.

Treatment staff should have frequent interaction with patients and should encourage ongoing dialogue concerning their symptoms. The counselor should make the patient feel comfortable in sharing information about all types of drug use and should not take a punitive approach if drugs other than opioids are used. Such interaction allows for rapid adjustments in dosage and for other interventions as indicated. Extended clinic hours increase the availability of treatment providers, especially if they are needed on an emergency basis during the first few weeks of this phase.

Frequent contact with staff should facilitate the rapid elimination of opioid and other drug use. Extra sessions of individual or group counseling during this period can provide an added measure of support. Intensified treatment within the substitution therapy program is an important response to continued use of illicit drugs and alcohol abuse. Although methadone directly affects only opioid use, reductions in nonopioid use typically occur in the context of good therapy and counseling during methadone maintenance.

If opioid use continues or alcohol and other drug use poses a threat to the patient's progress and safety, a referral to inpatient treatment for a short time may be necessary. For some patients, methadone treatment is not the most appropriate modality, and referral to another therapy may be indicated. In other cases, the patient may respond to a program in which detoxification from other substances is completed while methadone maintenance is continued.

Criteria for transition from the acute phase into the next phase of treatment are

- The amelioration of signs of withdrawal
- Reduction in drug craving
- Demonstrable reduction in opioid and nonopioid drug use.

Some signs that the acute phase has ended are

- A subjective feeling that the methadone is stabilizing or "holding"
- An increased sense of well-being
- Changes in bowel function (decrease in or resolution of diarrhea or possible constipation)
- At least a few opioid-free urine tests.

Signs that a change in methadone dosage is needed include

- Continued opioid or other drug use to relieve subtle withdrawal symptoms
- Subjective complaints that the dose is not stabilizing or "holding" in the absence of signs and
- symptoms of sedation
- Continued illicit activities that reflect drug-seeking behavior.

The signs and symptoms that a dosage of methadone is too high include

- Drowsiness, nodding
- Pinpoint pupils
- Slowed speech
- Respiratory depression and decreased vital signs
- Euphoria
- Flushing of skin.

Intensified treatment within the substitution therapy program is an important response to continued use of illicit drugs and alcohol abuse.

### Psychiatric Problems

Acute symptoms of depression and anxiety are common among persons applying for treatment of substance use disorders. These symptoms are often markedly reduced or disappear after methadone stabilization, but sometimes they represent independent disorders that persist and need more specialized treatment. Post Traumatic Stress Disorder (PTSD), anxiety disorders, schizophrenia, bipolar disorder, antisocial personality disorder, and the entire range of psychiatric disorders that are seen in non-substance-abusing populations are seen among persons with opioid dependence. It is extremely difficult to diagnose independent psychiatric disorders during the early part of the acute phase of treatment, and a definitive diagnosis must often wait until the patient is stabilized.

When psychiatric disorders are present, there is usually increased difficulty in treating the substance use disorder. When the psychiatric disorder is treated with pharmacotherapy, psychotherapy, or a combination of these approaches, the substance use disorder is more likely to improve than when the psychiatric disorder is not treated (Woody et al., 1984).

Identification of persistent, independent psychiatric disorders that need ongoing therapy should be a focus during the acute phase so that the appropriate matching strategies can be formulated and implemented. Acute, substance-induced psychiatric disorders that do not need ongoing treatment should also be identified. Although these disorders usually resolve when the substance use disorder is under control, they can be very disruptive at the start of methadone maintenance, and patients may also need focused, short-term pharmacotherapy or psychotherapy. Since their course usually follows that of the substance use disorder, they typically do not require ongoing psychiatric treatment.

### Medical Problems

The acute phase of treatment is often characterized by catastrophic medical problems requiring the use of significant and costly resources. These medical conditions must be stabilized before effective treatment can begin. Long-standing medical problems that may have been neglected during periods of drug use and prior to treatment entry must be addressed immediately. Such problems may include tuberculosis (TB), cellulitis, human immunodeficiency virus (HIV) infection, renal disease, diabetes, sickle cell trait or anemia, or cardiopulmonary diseases. Skin or organ abscesses secondary to repeated needle use or infection may require skin grafting, surgical correction, or aggressive pharmacotherapy. Any of these conditions may require hospitalization and incur substantial medical costs in a population that is typically lacking in financial resources.

As in the case of psychiatric problems, stabilization of acute medical conditions and the institution of ongoing care for chronic conditions are mandatory before a patient can move out of the acute phase of treatment.

Treatment programs should have arrangements in place to provide referral for hospitalization on short notice (see section later in this chapter on Hospitalization of Methadone Patients). In the absence of linkages to available resources, case management between the referring physician and hospital can facilitate this process. As in the case of psychiatric problems, stabilization of acute conditions and the institution of ongoing care for chronic conditions are mandatory before a patient can move out of the acute phase of treatment.

### Legal Problems

In communities where jails and prisons do not allow opioid substitution therapy, it is important to address a patient's legal problems as soon as possible after treatment is initiated. Ongoing criminal activity may result in a patient's abrupt removal from the community -- and from opioid substitution therapy. On behalf of those who are on probation or parole, program staff should make efforts to cooperate with criminal justice agencies. Staff can thus help clients to avoid incarceration, if appropriate, by making continued treatment one condition of probation or parole.

### Basic Needs

Patients' needs for basic necessities such as food, clothing, housing, and safety should be determined and referrals made to appropriate agencies. At the time of treatment entry, the chaotic lives led by many patients with opioid addiction often create legal, financial, and safety concerns that threaten survival. Homeless individuals should be referred to transitional shelters until more permanent housing can be secured.

Studies show that ease of access to the treatment facility is a predictor of retention in methadone programs (Condelli, 1993). Transportation problems may be addressed by introducing a new patient to other patients. It may also be helpful to keep a small transportation fund at the treatment site for new patients who lack resources or for emergency situations.

Treatment providers can help patients determine the extent of debts, financial or otherwise, that they may have accumulated in response to legal problems. They can also help patients deal with threats to their safety, giving special attention to threats from drug dealers or other individuals to whom they owe money. A legal advocate, eligibility case manager, or social worker can be very helpful during this phase in identifying critically needed financial resources. Linkage with a law firm that provides pro bono services can also be helpful.

Before a patient can be appropriately moved out of the acute phase of treatment, his or her basic need for food, clothing, shelter, and safety must be provided. The patient's living situation, if not entirely drug free, should at least be relatively stable and secure if treatment is to move beyond the acute phase of crisis management.

For transition from the acute phase into the rehabilitation phase, patients should also begin to develop skills to remove themselves from situations in which drug use is inevitable. If a patient is unable to gain this level of control, short-term inpatient treatment may be indicated.

### Therapeutic Relationship

Some patients may initially view methadone treatment as a short-term solution to opioid addiction (Lipton et al., 1992). Other patients may believe that methadone has deleterious side effects and that it is almost impossible to detoxify from this medication (Beschner and Walters, 1985; Goldsmith et al., 1984; Hunt et al., 1986; Magura et al., 1993). These and other myths must be dispelled before meaningful treatment can begin, as they may influence treatment engagement and compliance.

In addition to correcting misconceptions about treatment, the major task of the staff, particularly the treatment counselor, is to begin to educate patients about the goals of methadone treatment, the program, and the benefits that are possible as a result of compliance. The first step in this process is to build a relationship of trust. Simple psychotherapeutic listening techniques elicit the patient's views and feelings about his or her relationship with the program and the treatment providers. Providers can help patients create their own support systems by encouraging them to be involved in appropriate social and recreational activities.

Positive reinforcement of the patient's treatment engagement and compliance is important in eliciting commitment to the therapeutic process. The Center for Substance Abuse Treatment (CSAT) has published a manual Treatment of Opiate Addiction With Methadone: A Counselor Manual, which addresses the importance of the therapeutic bond between counselor and patient.

The treatment provider can help the patient make a commitment to the treatment process by

- Pointing out the negative aspects of the patient's former situation
- Identifying the benefits of treatment in terms of financial advantages, improved self-esteem, and enhanced sense of well-being
- Exploring and clarifying the patient's goals in treatment.

Patients should be introduced to key staff members of the treatment program as early as possible to foster an atmosphere of safety, trust, and familiarity. Relationships with other patients can also increase the patients' level of comfort within the program. During scheduled appointments, treatment providers should minimize waiting times whenever possible to demonstrate that patients' time is valued. In addition, when the provider remains flexible and available during acute situations, he or she contributes to the patient's sense of security.

Key signs of the beginning of a positive therapeutic relationship include regular attendance at group and individual counseling sessions and positive interactions with treatment providers. Signs that patients are progressing toward the next phase of treatment include their demonstrating compliance with the recommended treatment and then beginning to define and focus on the goals of treatment. Khantzian and associates did important work in developing effective therapeutic interventions for substance abusers (Dodes and Khantzian, 1991; Khantzian et al., 1990). Measures of therapeutic helpfulness, which can be used as indicators of the strength of the therapeutic relationship, were developed by Simpson and associates (1995).

### Motivation and Patient Readiness

Patient motivation to engage in treatment is a predictor of early retention (Simpson and Joe, 1993). The treatment provider may encounter obstacles to the development of self-motivation arising from negative attitudes toward treatment. Some of these attitudes may arise from past experiences, such as negative relationships with treatment staff, introduction of methadone treatment without needed support services, and inadequate methadone dosing.

Other potential obstacles to effective treatment include patients' ambivalence about giving up illicit drug use and fears of making major life changes. As mentioned above, many opioid users have mistaken beliefs about methadone and its effects, beliefs that can be serious obstacles to entering treatment. Even positive life changes can cause anxiety and stress when a patient is confronted with unfamiliar attitudes and situations. Several strategies have been developed to use the counselor-patient relationship to increase patient motivation (Miller and Rollnick, 1991).

Counselors should explore and openly address patients' past negative treatment experiences. It is helpful to suggest that many factors may have been responsible for such experiences and that these factors may no longer be as relevant as they once were. Emphasis should be placed on making a fresh start, letting go of old grievances, and focusing on current realities and goals. It may also help to acknowledge that the treatment staff may not have been as helpful as they could have been on previous occasions. To address patients' ambivalence about giving up drugs, providers should stress the benefits of methadone treatment in terms of preventing needle-borne infections, avoiding arrest and incarceration, and gaining peace of mind and relief of concerns over obtaining the next fix. Patients must be encouraged to recognize that, rather than being controlled by methadone, they can be empowered to gain better control over their addiction.

During scheduled appointments, treatment providers should minimize waiting times whenever possible to demonstrate that patients' time is valued. In addition, the provider's remaining flexible and available during acute situations contributes to the patient's sense that he or she can rely on the provider.

A commitment to the treatment process may be manifested by the patient's acknowledgment that his or her addiction is a problem. Before moving out of the acute phase, the patient must be motivated to make changes in his or her lifestyle and to address issues surrounding drug use.

## Rehabilitation Phase

The primary goal of the rehabilitation phase of treatment is to empower patients to function in the major life domains. The methadone dosage must be stabilized at a comfortable level prior to entering this phase. During the rehabilitation phase the patient undertakes efforts to become a responsible, functioning member of society.

Exhibit 3-3 summarizes the clinical issues that should be addressed during the rehabilitation phase, strategies for addressing them, and indicators for the transition from rehabilitation to the stabilization phase.

Exhibit 3-3 Rehabilitation Phase of Methadone Treatment: Clinical Issues, Strategies, and Issues for Transition to Supportive Care

Clinical Issues | Strategies to Address Issues | Indicators for Transition Into Supportive Care
Alcohol and Drug Use; - Continued use of abusable drugs (alcohol, cocaine, and others); - Continued opioid use | - Behavioral contracting; - Short-term inpatient treatment; - Disulfiram for alcohol abuse; - Intensification of treatment services; - Positive incentives: take-home medication, recognition of progress; - Intensified individual or group counseling; - Adjustments in dosage as necessary for continued opioid use; - Support groups | - Ability to identify and manage relapse triggers; - Repertoire of coping skills; - Demonstrated changes in life circumstances to prevent relapse; - Discontinuation of opioid and other drug use; - Absence of problematic alcohol use
Medical and Psychiatric Problems and Concerns; - Chronic medical diseases: diabetes, hypertension, HIV infection, tuberculosis, seizure disorders; - Psychotic, anxiety, mood, and personality disorders; - Pregnancy, dental problems, nicotine dependence | - Onsite primary care or linkage to other services; - Holistic approach; - Training on diet, exercise, smoking cessation; - Adjustments in other medications interacting with methadone; - Teach coping skills; - Individualized psychiatric care; - Early identification and referral for special psychiatric problems; - Referral for psychotropic medication or psychotherapy as indicated; - Ongoing evaluation of psychiatric status | - Compliance with treatment for chronic diseases; - Improved overall health status; - Improved dental health and hygiene; - Regular prenatal care; - Stable medical and mental health status
Vocational and Educational Needs; - Unemployment/underemployment; - Low reading skills; - Literacy; - Learning disabilities | - Targeting of patients with less than high school education; - Onsite GED counseling or referral; - Literacy and vocational programs; - Encourage local businesses to set up apprenticeships or entry-level positions; - Bring together business, government, and industry leaders to set up income-generating enterprise; - Training on budgeting of personal finances | - Stable source of income; - Actively seeking employment; - Involvement in productive activity: school, employment, volunteer work
Family Issues; - Absence of family support system; - Emergence of family problems (e.g., traumatic family history, problematic current situations) | - Involvement in community or church groups; - Join fellowship, recreation, or other peer group; - Increased involvement in family life (in absence of family dysfunction that impedes progress); - Encourage well-baby care | - Social support system in place; - Absence of major conflict within support system; - Increased responsibility for dependents
Legal Issues; - Criminal charges; - Custody battles; - Ongoing illegal activities | - Access to legal counsel; - Encourage patient to take responsibility for legal problems; - Identify obstacles to eliminating illegal activities and replacing them with constructive activities | - Resolution of, or ongoing efforts to resolve, legal problems; - Absence of illegal activities

Early in the rehabilitation phase, treatment providers can assist or refer patients who need help with legal, educational, employment, and financial problems. If not addressed with high-quality services, these problems can result in patients' dropping out of treatment (Condelli, 1993). As described in the previous section, serious problems that threaten a patient's continued treatment, such as ongoing criminal activity and serious financial problems, should be addressed as soon as possible after treatment is initiated.

In the rehabilitation phase, efforts should begin toward productive participation in constructive activities such as full- or part-time employment, education, vocational training, childbearing or homemaking, or volunteer work.

### Alcohol and Illicit Drug Use

Continued use of alcohol and other abusable substances, including nonopioids such as cocaine, amphetamines, benzodiazepines, and sedatives, poses obstacles to patient progress in any phase of treatment. During the rehabilitation phase, use of illicit drugs and alcohol may even precipitate a patient's regression to the acute phase. A previous Treatment Improvement Protocol (TIP) State Methadone Treatment Guidelines has a chapter on treating alcohol and other drug use in methadone patients, while this TIP provides only a brief overview.

Continued use of opioids must also be identified and adequately addressed to discourage the use of other drugs (Dunteman et al., 1992; Fairbank et al., 1993) and prevent relapse. The frequency of urinalysis during this phase should depend upon the patient's progress in treatment. Once a patient is stabilized and is progressing well in the rehabilitation phase, with a series of negative urinalyses, the frequency of random urinalyses can be decreased to once or twice a month. Such decisions should be part of the overall treatment plan.

In the rehabilitation phase, efforts should begin toward productive participation in constructive activities such as full- or part-time employment, education, vocational training, childbearing or homemaking, or volunteer work.

Behavioral contracting is a useful strategy to address continued drug use in the rehabilitation phase (Chambers et al., 1972; Condelli et al., 1991; Glosser, 1983; Stitzer et al., 1986; 1992 ). Essentially, this strategy requires the patient and treatment provider to identify and discuss treatment goals and expectations. Generally, the patient is then asked to sign an agreement that specifically outlines the objectives to be achieved, the behaviors to be avoided, and the consequences that will occur if the patient fails to comply with the agreement. To be effective, the details in such a behavioral contract must be worked out with the patient and mutually agreed upon.

Strategies for reducing various types of drug use among methadone patients have been described, including the use of disulfiram (Antabuse), prescribed as a deterrent to alcohol use; short-term inpatient treatment for detoxification to achieve stabilization; and intensified treatment services, such as more individual and group counseling sessions (Kosten, 1991; Kreek, 1991). Other strategies include confrontation of negative behaviors and use of unprescribed drugs (Chambers et al., 1972) and provision of positive incentives in the form of take-home medication and recognition of progress (Stitzer et al., 1992).

In the rehabilitation phase, information about outside support groups that was first introduced during the acute phase should be periodically reviewed. Providers should also cultivate relationships with churches and community groups to provide support and facilities for methadone patients and, in the process, to educate the community and dispel myths about methadone.

To be eligible for transition from the rehabilitation phase, patients should be able to identify relapse triggers that remain after some of the more troublesome ones have been eliminated during the acute phase. Examples of triggers are boredom, passing by specific locations, spending time with specific individuals, having unresolved family problems, or experiencing psychiatric symptoms. Emphasis should be given to helping patients develop and maintain coping skills to deal with these triggers (Sandberg and Marlatt, 1991). These skills often involve anticipating responses when confronted with relapse triggers and rehearsing appropriate responses with the help of the counselor. A related and very important activity is to begin to make proactive changes in lifestyle and circumstances that will reduce the chances for relapse.

Discontinuation of all illicit drug use is mandatory by the end of the rehabilitation phase. Continued heavy alcohol use that is problematic and interferes with functioning will prevent the patient from moving beyond the rehabilitation phase and, for some patients, will require return to the acute phase.

### Ongoing Health Concerns

Opioid users admitted to methadone programs are those who are at a notably increased risk of HIV infection and acquired immunodeficiency syndrome (AIDS), multidrug-resistant tuberculosis, and other infectious diseases (Chaisson et al., 1989; Graham et al., 1992; Novick et al., 1990; Schoenbaum et al., 1989). They may also have chronic medical conditions such as diabetes, hypertension, or seizure disorders that require them to be referred for ongoing treatment. In addition, many opioid users neglect dental care. Once heroin use is reduced, they may experience dental pain because the pain-killing effects of opioids have been eliminated.

In general, medical care for methadone patients should be identical to that provided for other patients. In some cases, however, dosages of medications for medical conditions may need to be adjusted because of interactions with methadone. For example, Dilantin (diphenhydantoin, phenytoin) and rifampin both tend to lower serum methadone levels and may thus require the methadone dosage to be adjusted upward. Onsite primary healthcare is optimal. When inadequate resources prohibit onsite medical services, linkages to other services should be in place. A holistic approach addressing all aspects of the patient's health will facilitate attention to neglected medical problems. Education and training about diet, exercise, personal hygiene, and smoking cessation are important. The counseling staff can use printed educational material or videotapes to present these messages.

Continued heavy alcohol use that is problematic and interferes with functioning will prevent the patient from moving beyond the rehabilitation phase, and for some patients, will require return to the acute phase.

Patients must adhere to medical care for chronic diseases and such conditions must be under control before patients can be considered for transition to subsequent phases of treatment. Improved overall health status, as well as improved dental health and hygiene, is a criterion for transition to a subsequent phase of treatment.

### Employment and Other Income-Related Issues

Some of the most difficult obstacles faced by patients attempting to stabilize their lifestyle include unemployment and inadequate funds for living. Poor reading skills and lack of education contribute to the difficulties they face in obtaining stable employment. Employment opportunities in the patient's community may be lacking, even for individuals who are not handicapped by a history of AOD use.

Research suggests that males with less than a high school education have particular difficulty in negotiating for and obtaining high-quality social services (Condelli, 1993). Access to services may be a problem for many patients, both males and females, who have been addicted to drugs for years. These individuals should be targeted for educational, literacy, and vocational programs to equip them with the skills necessary to function independently. Included in these programs should be education and training about budgeting personal funds and setting up bank accounts.

Ideally, treatment programs should provide onsite counseling for the general equivalency diploma (GED). This service is rarely available onsite because of resource limitations. Therefore, a program should be able to make referrals to local adult education programs. Local businesses and industries can be encouraged to set up apprenticeships or entry-level positions. Efforts can be made to bring together business, industry, and government leaders to set up income-generating business enterprises that can provide clients with job skills and create opportunities for their entry into the job market.

By the end of the rehabilitation phase, patients should be employed, actively seeking employment, or involved in a productive activity such as school, childrearing, or regular volunteer work. It is most important that patients have a stable source of legal income, whether from employment or other sources, to ensure that they will not resort to drug dealing or other criminal activities.

### Family Relationships and Social Supports

No family can escape the stress and conflict that are brought on by another family member's addiction to drugs. Broken trust, disappointment, anger, and conflict are the realities that patients in treatment must come to face during the rehabilitation phase. Many of these individuals have been cast out of their families and have been surviving in the absence of a family support system.

During the rehabilitation phase, the counselor should help the patient build social supports and relationships, as well as rebuild and heal what are often severely damaged family relationships. The patient can gain social support by becoming involved in community or church groups or by joining a fellowship or a recreational or other peer group. It is important for these groups to understand and accept methadone therapy so that patients are not stigmatized. Increased involvement in family life should also be encouraged, in the absence of major family conflicts or dysfunction that might impede the patient's progress in treatment.

In addition, family problems that may have contributed toward the addiction will often emerge in the context of counseling during the rehabilitation phase. In such cases, staff must help patients attempt to come to terms with the impact of these traumatic family histories. Referral for family therapy may be appropriate in some cases.

Transition out of the rehabilitation phase requires that patients have a social support system in place that is free of major conflicts. Another positive indicator for transition emerges when the patient assumes increased responsibility for dependents (such as reliably paying or providing child support).

### Legal Problems

Criminal charges, custody suits, and ongoing illegal activities are among the legal issues faced by many patients in treatment. Any of these problems can easily precipitate a relapse to illicit drug use, and all must be addressed as thoroughly as possible.

Counselors may have to probe into personal legal issues such as custody status and obligations. Many patients ignore these issues during periods of addiction; however, these issues may pose a serious threat to ongoing recovery. Patients should be encouraged to take responsibility for their own legal problems. The counselor may need to help the patient overcome guilt, fear, or uncertainty in relation to these problems. In addition, the treatment program must ensure that patients have access to adequate counsel to handle their legal problems. These services are often provided by the public defender's office.

It may be difficult for some patients to extricate themselves from continued illegal activities, for either economic or social reasons. Nevertheless, efforts must be made to identify obstacles to eliminating these activities and finding ways to replace them with constructive, legal activities. All major legal problems should be resolved -- or be in the process of resolution -- and all illegal activities should cease before patients can move beyond the rehabilitation phase.

By the end of the rehabilitation phase, patients should be employed, actively seeking employment, or involved in a productive activity such as school, childrearing, or regular volunteer work. They must have a stable source of legal income from employment or other sources to ensure that they will not resort to drug dealing or other criminal activities.

### Psychiatric Problems

Depression, anxiety, and insomnia are common in patients undergoing treatment for opioid addiction in any phase of treatment. As discussed earlier, these problems may pose obstacles to progress in treatment. Complaints of boredom are often a signal of depression. A wide range of other psychiatric problems may emerge during methadone treatment and may need to be addressed concomitantly with problems of substance use.

Patients should be taught coping skills to deal with frustration, anxiety, and boredom. Treatment staff should provide individualized care and should be sensitive to each patient's mental health status. Particular problems should be identified early and referrals made to appropriate resources. When indicated, a referral should be made for psychotropic medication, and patients' psychiatric status and use of medications should be evaluated on an ongoing basis. Because of the abuse potential of benzodiazepines, caution should be used when prescribing this type of medication (see Chapter 4). Anxiety disorders in this population have been effectively treated using tricyclic antidepressants rather than benzodiazepines. The latest edition of the Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition (DSM-IV) (American Psychiatric Association, 1994) describes a wide range of substance-induced psychiatric disorders and presents guidelines for determining when symptoms represent an independent disorder.

Before a patient can move out of the rehabilitation phase, psychiatric problems must be alleviated or stabilized. Although many psychiatric symptoms may continue to arise throughout the course of a patient's life, he or she should have adequate coping skills to prevent these symptoms from precipitating a relapse to drug addiction.

Finally, it is important to note that in many cases, when patients report persistent difficulties in several life areas, such as family and social relationships and employment, they may have a personality problem. Often, the patient is not aware of the role of his or her personal style in creating problems. The patient's irritable behavior or suspicious, aggressive attitude may create a host of problems. Other personality problems that have been described in this population include low self-esteem and self-confidence, low tolerance for distress, impaired regulation of emotion, chronic anxiety and anger, and antisocial attitudes. Often these serious and disabling personality problems do not meet the diagnostic criteria for psychiatric disorders.

Observation and interaction with the patient over a period of time is often required to detect personality problems. Information from family members, employers, probation and parole officers, and others may be needed to clarify the problem. Most patients with these kinds of problems are not interested in or accessible to psychotherapy. A long-term therapeutic relationship with an understanding counselor can sometimes help them gain insight. Counselors working with these types of patients can be greatly helped by periodic psychiatric consultation. A previous TIP in this series, Assessment and Treatment of Patients With Coexisting Mental Illness and Alcohol and Other Drug Abuse, provides guidelines for working with AOD-abusing patients who have been diagnosed as having personality disorders, especially antisocial and borderline personality disorders.

## Supportive Care Phase

After meeting the criteria for transition out of the rehabilitation phase, patients enter a phase in which they receive mainly supportive care. During this phase, most patients begin to receive take-home medication for longer periods and have less frequent contact with treatment staff. As the patient is getting ready to receive take-home medications, it may be a good idea to increase the frequency of urinalyses for a brief period. Similarly, once take-home privileges are granted, more frequent urinalyses during the initial stages may help the patient maintain progress.

After remaining abstinent (as confirmed by negative urine tests) for a specified period, some patients may be considered for transition into medical maintenance or medication tapering (medically supervised withdrawal from methadone). The period of time that a patient should remain in supportive care is entirely dependent on his or her individual needs. The domains and issues described above for ongoing assessment during the acute phase and rehabilitation should continue to be assessed at least quarterly to determine whether the patient is eligible and appropriate for transition into medical maintenance or methadone tapering.

Some patients may have stopped opioid use and demonstrated compliance with program rules, but have not made progress in other areas. Although they may be doing well in treatment, these patients need the ongoing support and pharmacotherapy provided by the program. They are ineligible or inappropriate candidates for either medical maintenance or methadone tapering, even after an extended period of time in supportive care. These patients should remain in the supportive care phase, receiving take-home medication and a reduced level of services in accordance with their needs. This option is usually appropriate for patients who are functioning relatively well with methadone treatment but who have mild to moderate problems that make them poor candidates for the markedly reduced level of services associated with medical maintenance or for the reduction in methadone dosage that is part of tapering.

## Medical Maintenance Phase

Patients who have achieved a high degree of stability and are able to function effectively but who continue to need methadone to maintain this level of stability can be considered for medical maintenance. In this phase, patients can maintain stability on methadone and have a lifestyle that does not revolve around frequent visits to the clinic. Patients receiving medical maintenance typically are seen by their counselor or therapist once or twice a month and receive up to 6 days' supply of take-home methadone.

Some patients may be doing well in treatment, while remaining ineligible or inappropriate for either medical maintenance or methadone tapering, even after an extended period of supportive care. These patients should remain in the supportive-care phase, receiving take-home medication and a reduced level of services in accordance with their needs.

If the patient remains stable, productive, and drug free in this phase for several months or longer, the amount of take-home medication can be increased to a 2-week supply under some circumstances. Under current regulations, such a schedule is an exception and must be approved in advance by the methadone monitoring office of the Food and Drug Administration (FDA). Two-week take-home doses must also be approved by the State Methadone Authority. When dispensing take-home medication, it should be kept in mind that patients can deteriorate quickly, and thus regular visits to the clinic and urine tests are important parts of treatment during this phase.

The following criteria should be considered to determine a patient's eligibility for medical maintenance:

- Number of years in methadone treatment (at least 3 years under current FDA guidelines)
- Elimination of drug use for at least 1 year
- Noninterfering alcohol use (as assessed by use of the CAGE questionnaire, liver function test results within normal parameters, and leukocyte and erythrocyte elevations or decreases)
- Stable living conditions in a drug-free environment
- Source of stable income
- Involvement in productive activities (employment, school, volunteer work)
- No criminal or legal involvement (such as facing charges) for the last 3 years; not on parole or probation
- Adequate social support system and absence of significant psychiatric problems.

In addition, ongoing evaluation of the domains outlined in the descriptions of the acute and rehabilitation phases should take place during medical maintenance. Also recommended during this phase are random urine testing and random callbacks of medication. Callbacks involve requesting patients to bring in their remaining supply of take-home medication once every 3 to 6 months. This procedure allows treatment staff to take an inventory of medication to ensure that it has not been diverted to others. However, such callbacks are not required by FDA regulations. If evidence of diversion is found, the patient should return to the appropriate earlier phase of treatment. Reinstatement into medical maintenance should not be implemented until program staff have closely observed the patient over an extended period (3 to 12 months or longer) in the appropriate earlier phase, and the patient has again demonstrated the required level of progress in treatment and appropriateness for medical maintenance.

Some patients may need indefinite or lifetime methadone maintenance, along with concurrent psychosocial and rehabilitative services. Some long-term stable patients can eventually be managed on lower dosages (20-60 mg), with fewer side effects than the higher dosages required at the start of treatment. Others may need to continue taking the same dosage of methadone but may not require ongoing rehabilitative services. These patients may be appropriate for medical maintenance, and they should be permitted to continue in this phase indefinitely provided they continue to meet its inclusion criteria.

## Tapering and Readjustment Phase

### Tapering

Most patients who choose to detoxify from methadone do so gradually. Successful rapid detoxification has been reported using naloxone to precipitate withdrawal, and clonidine to suppress acute symptoms; the patient is then inducted onto naltrexone (Kleber et al., 1987; Resnick et al., 1976). Tapering is a term commonly used to describe the gradual reduction and elimination of methadone treatment. Medically supervised withdrawal is another term for this process.

In determining patients' eligibility for methadone tapering, their preferences and desires should be taken into account, with the understanding that they can return to their previous methadone dosage if tapering is not successful. Some level of discomfort during this process is inevitable, even if the dose is reduced very slowly over a period of months. A dose of 20 to 30 mg is the level below which symptoms are usually most problematic.

As medication is being tapered, services should be intensified in the form of increased monitoring of behavioral and emotional signs and increased counseling sessions. A patient being considered for methadone tapering should be sufficiently motivated to undertake this process, with the intensified counseling and increased participation in therapy sessions that it entails. Putting pressure on patients to enter this phase of treatment can have very negative results.

Counseling on the issue of tapering may consist of helping the patient to differentiate between excessive or even phobic fears of withdrawal symptoms (Milby et al., 1987) and the normal concerns that are a part of detoxification. Examples of the former are fears that one cannot live without methadone, or excessive anxiety at even the thought of detoxification. Normal concerns include worry about relapsing, how to structure activities when daily clinic attendance is no longer necessary, and how to create support for a drug-free lifestyle in the absence of regular ingestion of methadone.

In addition to physiological symptoms associated with detoxification, many patients develop a psychological dependence on the treatment program. Issues regarding loss of support may arise. These problems are usually identified in the early phases of detoxification or even before it begins.

The risk of relapse during and after tapering is significant, owing to the physical and emotional stress involved in attempting to discontinue methadone treatment. Patients should be strongly encouraged to discuss any difficulties they experience with tapering and readjustment so that appropriate action can be taken if this approach fails and relapse can be prevented. The patient should be encouraged to return to a previous phase if it is indicated at any time during tapering.

Important factors in a decision to taper medication include

- The patient's wishes and preferences
- The patient's level of motivation
- Length of addiction
- Results of previous attempts at tapering
- Family involvement and stability.

### Withdrawal and Postwithdrawal Symptoms

Withdrawal symptoms such as insomnia, anxiety, cravings, or dysphoria are common, and the patient should be told to expect these symptoms during tapering, especially when lower dosages are reached (below 20-30 mg a day). Patients should be instructed about the normal course of these symptoms and the importance of tolerating them without recourse to opioid use. Several options exist for the amelioration of these symptoms. Medication can be tapered more slowly, lengthening the intervals between decreasing dosages, or the current dosage can be held at a steady level until symptoms abate. Other medications can be used to address specific symptoms. Clonidine may be instituted to control generalized withdrawal symptoms, both during or after methadone treatment. However, it should be used with caution because of its ability to reduce blood pressure.

In some cases single, low methadone doses (5 to 10 mg) can be given once or twice after completing the taper to reduce the intensity of symptoms and give the patient temporary relief from the peak of symptoms that occurs during the several days following discontinuation of daily methadone. Acupuncture has also been used to address withdrawal symptoms during methadone tapering, although its efficacy has not been adequately evaluated as of this writing (see Chapter 4). Finally, inpatient treatment may be indicated for addressing withdrawal in some patients, while others may participate in intensive outpatient rehabilitation.

For a minority of opioid-addicted persons, use of opioids helps reduce relapse to an underlying psychosis. In the past, the use of opioids and opioid blockers in the acute treatment of schizophrenia was explored (unsuccessfully) because clinicians had observed these antipsychotic effects. However, opioids seem able to help stabilize remissions in people whose acute psychotic symptoms have been controlled. Psychiatric assessment should be ongoing throughout all treatment phases.

### Readjustment

Patients who complete tapering from methadone enter a period of readjustment. The reduced contact with the clinic often creates anxiety. Additional counseling is usually needed at this time. Emphasis should be placed on reinforcing the patient's coping and relapse prevention skills. The patient's primary goal during readjustment is to develop greater self-sufficiency and to create and maintain a balanced, stable, and productive lifestyle. Participation in self-help or support groups is continued during the readjustment period as dependence on the treatment program is gradually reduced. After successful completion of tapering, some patients may be helped by continued naltrexone therapy, an effective, long-lasting opioid antagonist that will block opioid effects for 2 to 3 days when given in appropriate doses. It may help motivated patients remain opioid free by creating a chemical barrier and behavioral disincentive.

Special attention and support should be provided during the first 3 to 12 months following medically supervised withdrawal, when most relapses occur. Support should be focused on fostering self-sufficiency and reinforcing the goals of treatment. Other strategies to help patients after the completion of tapering include

- Problem-solving counseling approaches
- Reinforcement of positive behaviors and attitudes
- Maintenance of an open-door policy to maximize
- the availability of counselors and providers
- Use of the patient's support system, such as self-help groups, to benefit the recovery process.

### Reversion to Methadone Treatment

Even under the best of circumstances -- with a highly motivated and stable patient and with strong family and social support systems in place -- there is no guarantee that tapering will be successful. Because many patients find that they cannot complete tapering, all patients in this phase should be carefully counseled to understand that a return to a higher methadone dosage does not represent a failure, either of the treatment program or of the individual. A return to a previous phase may simply be an indication that the ongoing use of methadone may be more appropriate, at least for the present time. For many patients, the optimum outcome that can be achieved is continued functioning on methadone. Patients also need to understand that tapering can be restarted at any time, when both patient and staff feel it is appropriate.

### Indicators for Transition

Successful discontinuation of methadone is the key indicator for transition from the tapering phase. Another primary indicator for transition is the patient's transformed identity. Development of a positive self-view as functioning well without methadone and adoption of a socially productive lifestyle without involvement in drugs or alcohol is critical to the completion of this phase and to continued recovery. The absence of signs and symptoms of dependence or abuse, as defined by the DSM-IV or the International Classification of Diseases, Tenth Edition (ICD-10) (see Chapter 2), and negative urinalyses and breath tests for nonprescribed abusab le substances are criteria that must be met before the tasks and goals of this phase are complete. Continued participation in self-help groups is often helpful for the reinforcement of coping and relapse prevention skills. Finally, the patient should have achieved and maintained relative stability in all of the life domains discussed above.

## Aftercare Phase

Aftercare is a phase that follows successful tapering and readjustment; it is based on clear evidence that recovery is well under way. As discussed above, the patient has adopted a socially productive lifestyle, is no longer involved with drugs or alcohol, and has demonstrated appropriate coping skills over a period of at least 1 year. Persons in this phase are often involved in regular attendance at self-help groups, and regular treatment is no longer necessary, except to keep open contact with treatment providers and to ensure that recovery continues. During this phase, appointments may be scheduled every 1 to 3 months, although many programs prefer that patients maintain monthly contact. The period for which patients are monitored in aftercare varies among programs, but many consider 6 to 12 months to be a reasonable time.

Persons in the aftercare phase are often involved in regular attendance at self-help groups, and treatment is no longer necessary except to keep open contact with treatment providers and to ensure that recovery continues.

Some patients may not need aftercare services, preferring a complete break from the clinic. Others may need more extensive aftercare and a referral to a nonmethadone outpatient treatment program. As with any chronic condition, an unfortunate tendency exists for care providers not to see patients until their condition is out of control again (a full-blown relapse). It is helpful to develop a structure to reduce the chances of such an adverse event. Periodic recall of patients, perhaps annually or semiannually, is one effective method that some programs use to keep in touch with patients. Another way to maintain regular contact with patients, if resources permit, is to set up a monthly or quarterly "alumni" group that brings together former patients of the program. As in the treatment of all addictions, treatment effectiveness is usually improved if the patient becomes involved in self-help groups, such as Narcotics Anonymous and Methadone Anonymous.

## Transition Between Phases, Discharge, and Readmission

### Transition Between Phases

The treatment system must be flexible enough to allow for transition from one phase to another according to the patient's progress. For example, crises or stressful life circumstances, such as financial debt or psychosocial stressors, may overwhelm a patient who resumes drug use in the belief that he or she is now "cured" and can control this behavior. Patients are often presented with opportunities for opioid use in their social environment. They may be tempted to test themselves to find out whether they are able to use opioids only once. Such individuals often rapidly regress to addictive behaviors that warrant transfer to the acute phase.

Occasional relapses to drug use may not require that a patient reenter the acute phase, but intensified counseling, loss of take-home privileges, dosage adjustments, or all of these interventions may be needed. If a patient is in the medical maintenance phase or the tapering and readjustment phase, a relapse almost always requires an immediate change of phase. In such cases, the patient would be considered in the rehabilitation phase once again. After providing evidence that the problems are well under control, the patient may be able to return to supportive care or medical maintenance.

A simple checklist, based on seven basic spheres of functioning (see Exhibit 3-4), that can be completed by case managers on a regular basis may facilitate monitoring of treatment progress. Factors warranting consideration of transfer to another phase can be recorded and periodically reviewed. Such a record can also be referred to in later treatment phases for information about a patient's earlier treatment experience.

Exhibit 3-4 Progress Notes

Patient ID #: _____________________________ Date: ______/______/______ Patient Name: ________________________________________________________________ Case Manager: ________________________________________________________________ Methadone Dosage: ________________________________________________________________ Results of last Urine Toxicology Screen: ____ Positive ____ Negative
1. Medical Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
2. Employment Sphere (including education and training): _______ Satisfactory ______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
3. Alcohol Use Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
4. Drug Use Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
5. Legal Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
6. Family Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
7. Psychiatric or Psychological Sphere: _______ Satisfactory _______ Unsatisfactory Comments: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________
Recommendations: ________________________________________________________________ ________________________________________________________________ ________________________________________________________________ ________________________________________________________________ ________________________________________________________________ ________________________________________________________________ Signature: ___________________________________ (Case manager)

### Voluntary Discharge

If a patient-requested voluntary discharge is against the advice and judgment of the treatment provider, a note should be made to that effect in the discharge plan. If the patient has made substantial progress and is in good standing with the program, efforts should be made to determine why he or she is requesting a discharge. Patients who are using heroin or other illicit drugs should be strongly discouraged from undergoing voluntary detoxification.

Efforts to resolve problems should be made to retain the patient in treatment. A referral can be made to another program that is more appropriate for the patient's needs at that time. Patients with a history of failed attempts at medically supervised withdrawal who request discharge should be counseled and educated about their risk of relapse and encouraged to stay. It may also be helpful to review the patient's treatment and relapse history to help the patient realistically assess his or her situation.

When these measures fail and a patient insists on leaving treatment, the discharge plan should allow him or her to reverse the decision at any point. The patient should be given the opportunity to return after discharge, and reentry into the program should be made as easy as possible.

### Involuntary Discharge

#### Decisionmaking

All programs must develop, disseminate, and consistently enforce guidelines for the management of patients who fail to comply with program rules. Program rules and the terms under which patients can be involuntarily discharged from the treatment program should be explained clearly to the patient. These rules should also be posted within the clinic, along with a description of the mechanism to appeal such decisions. Staff members should identify problems as they emerge and respond to them promptly.

The response must be tailored to the degree of severity of the problem. Patients should not be disciplined by having their methadone dosage lowered, nor should they be rewarded for good conduct by having the dosage raised. Programs are encouraged to develop nonpunitive ways to set limits and to contain problematic behavior. However, in some cases, involuntary discharge becomes necessary. Program staff are responsible for ensuring the safety and security of all patients and employees. This responsibility entails a clear need to maintain order, safety, and discipline within the building and grounds of the treatment program.

The terms for involuntary discharge vary among programs. Infraction of some rules may mean mandatory discharge, whereas other cases must be clinically evaluated in light of individual circumstances. Generally, behaviors that threaten the safety of the staff, patients, or the integrity of the program lead to automatic discharge. Examples are fighting, making threats, bringing weapons into the program, falsifying urine specimens, drug dealing, or diverting methadone. If the offense is not one for which suspension is mandatory, the patient's motivation and progress in treatment should be taken into account in determining whether he or she should be discharged, placed on probation, or merely warned. No patient should be discharged for minimal drug use.

Each treatment program must decide what level of drug use, over what period of time, is grounds for discharge. This decision will vary among programs. Some may allow only minimal drug use, whereas others may tolerate some repeated use unless the patient fails to comply with the treatment or counseling program or breaks program rules. Other clinics operate on the philosophy that, regardless of the level of drug use, patients should be kept in treatment, where they can be continually encouraged to stop their drug use.

It may be necessary to set some limits on patients who continue illicit drug use. The types of drugs used and their potential for serious adverse effects should be considered. For example, a patient who is dependent on large doses of alcohol, barbiturates, benzodiazepines, or other nonbenzodiazepine sedatives is at high risk of overdose or accidental injury and should immediately be considered for transfer out of methadone treatment until the sedative dependence is better controlled. Another important consideration in cases of unremitting drug use is its impact on other patients. A program's excessive tolerance of continued illicit drug use or total reluctance to set limits on use can diminish patients' respect for the overall program, as well as the respect of the community and other agencies.

Programs should consider for discharge only those persons judged to be "nonresponders" to methadone treatment despite the best efforts of the staff. If these patients do not keep appointments, do not comply with other aspects of the program, and do not put forth even minimal efforts to work with the staff toward appropriate treatment goals, discharge or transfer to another treatment modality is probably indicated. Essentially, such cases involve individuals who are not trying, whose progress in reducing drug use and achieving other goals is minimal or absent, and who would probably be doing about as well even without treatment.

However, it is important to note here that discharge in cases of treatment nonresponse is the last step in a long series of careful assessments and interventions. When a patient fails to improve, the first response should be to review the treatment plan and intensify treatment to match the patient's clinical status. Most programs have at least a limited capacity to intensify treatment by adding an extra 30-minute session of individual counseling or by requiring a group session weekly. Seeing poorly performing patients more frequently, even for less time each session, enhances the overall structure of treatment, which is a critical factor for many patients in opioid substitution therapy.

In any case, the decision to discharge for drug use should not be made solely on the results of urine testing; rather, a range of factors should be considered. Each clinic should set standards and be consistent, keeping in mind the benefits and drawbacks of the chosen approach. Clinics that are more tolerant may have higher rates of drug use and greater retention of patients in treatment, but they may risk fostering negative attitudes in non-drug-using patients. Programs that are less tolerant will have less drug use but may also risk losing patients who have the potential to benefit from treatment, especially over the longer term. Such patients are likely to be those with significant psychiatric or other associated problems and who may eventually respond to treatment, provided the appropriate blend of counseling and additional services can be arranged.

Another reason for involuntary discharge may be inability to continue to pay for program services. Discharge for nonpayment of program fees should be preceded by formal warnings from the program and efforts to help the patient change his or her behavior. For example, to prevent discharge for failure to pay, the patient should be advised to inform the program of impending financial problems as soon as possible. Staff will then have time to investigate other treatment, payment, or program alternatives. In any case, discharge should not occur until all efforts to secure reimbursement have been exhausted. Whenever possible, discharge should occur within the context of referral to another center with a sliding fee scale or to a State-subsidized program.

Involuntary discharge of patients who are HIV positive or who have AIDS creates a dilemma for staff. Concerns that the HIV-positive patient will resume needle sharing and transmit the virus often lead staff to ignore noncompliance issues in this patient group to retain the patient in the program. However, if staff suspect that the patient is continuing to share needles while attending the program, they also have strong concerns that ignoring noncompliance is "enabling" the patient to put others at risk. As discussed below, programs should make every effort to retain patients in treatment regardless of their HIV status. If a patient must be discharged, referrals should be made to a more appropriate level of treatment or to other substitution therapy programs. These considerations are especially important with HIV-positive patients and those with AIDS. The TIP Providing Treatment for HIV-Infected Alcohol and Other Drug Abusers provides further discussion of these issues.

#### Retaining Patients in the Program

Regardless of individual clinic policies, however, drug-using patients should not be allowed the same privileges (such as take-home medication) as other patients. Neither should their behavior be tolerated indefinitely without some type of intervention. Before discharging a patient for nonresponse to treatment, every effort should be made to provide the most appropriate treatment available for that individual's specific problems, and to persuade him or her to become fully engaged in treatment and to discontinue drug use. Approaches may include

- Intensive counseling
- Additional psychotherapy, pharmacotherapy, or combinations of both for psychiatric disorders
- Treatment of medical or other associated problems
- Inpatient detoxification with return to methadone treatment
- Change of counselors, if clinically indicated
- Alternative medications (for example, levo-alpha-acetyl-methadol [LAAM])
- Dosage adjustments
- Family intervention.

#### Discharge Procedures

If a decision is made to discharge a patient, discharge procedures should be initiated and withdrawal of methadone begun. Involuntary discharges should be made with the understanding that the patient may return to the program, provided that identified preconditions have been met, within a specified period of time. Obstacles to reentry should be minimized if the requirements are met. Even when a patient is discharged for drug use, the door should still remain open for his or her return, provided that the patient demonstrates that methadone treatment can help (for example, by doing well in another program). It may be advisable in some cases to schedule a date to invite the patient back to talk about whether he or she may reenter the program. Patients in treatment often fare better when their care is provided by a single provider group, even if treatment is episodic rather than continual.

#### Medical and Psychiatric Safety

Serious medical or psychiatric problems sometimes make it inadvisable or impossible for a patient to continue in a particular program. Ideally, patients benefiting from methadone therapy should be permitted to continue with this treatment in other settings, whether medical or psychiatric. Toward this end, treatment staff should work closely with other providers who treat the patient after transfer from the methadone program.

If attempts to facilitate continued medication in another setting are unsuccessful, a program of detoxification may have to be started. The facility to which the patient was transferred should make a referral back to the methadone treatment program as part of the patient's discharge plan. In such cases, the patient should be reassessed before resuming opioid substitution therapy, because his or her status may have changed.

#### Incarceration

Methadone treatment is almost always discontinued for patients who become incarcerated. Only one methadone maintenance program for incarcerated opioid-addicted offenders is known to exist in the United States, and that is at Rikers Island, New York City's central jail facility (Magura et al., 1993).

The treatment program should extend its best efforts to work with the penal facility and ensure that the appropriate detoxification procedures are used. Upon release from incarceration, patients who desire readmission should be reassessed to determine the appropriate treatment phase.

### Readmission

Readmission to methadone treatment is a common issue that must be anticipated. Marsh and associates (1990) reported that among the addicted patients they studied, multiple treatment admissions occurred over a 12-year followup period, with an average of more than six program admissions for each patient, most often involving methadone treatment. Patients being readmitted, whether from the same program or from other programs, should be placed in the phase of treatment that offers the most appropriate level of care.

To determine the appropriate phase, all key domains of functioning should be assessed to identify any factors warranting the patient's placement in a particular phase. The length of time the patient has been out of treatment should be taken into account. A complete reintake assessment is likely to be in order if this period is longer than 1 month, but is probably not necessary if the patient has had a shorter absence from treatment. The patient's history of drug use and performance while outside the treatment program, as well as any legal requirements, are also important factors to consider in this decision.

#### Review and Appeals Processes

Opioid substitution therapy programs should have written guidelines under which cases of involuntary discharge may be appealed and examined by staff -- generally, clinical staff. Some States have developed regulations to guide this process, partly to ensure that it will be impartially conducted. In these States, the reviews and appeals are administrative rather than clinical procedures. Whether the process is regulated by the State or not, most programs have established a formal mechanism whereby the appeal is referred to consecutively higher levels of program authority. Staff members who are directly involved with the disciplinary action should not conduct the review procedure. Appeals should be handled promptly.

## Clinical Issues Throughout All Treatment Phases

A variety of clinical issues arise during methadone treatment, and some may arise during more than one phase. Dispensing take-home medication and ensuring continued medication for patients who enter the hospital are discussed here.

### Take-Home Medication

Medication dispensed for patients to take home may begin on a gradual basis during the rehabilitation phase for patients who meet Federal eligibility criteria. These criteria require that the person demonstrate the absence of drug use by urine testing and attend the clinic and counseling sessions regularly. Other signs of rehabilitation such as working or being in school should also be evident, and program staff must judge the patient to be responsible for taking the medication as prescribed. Although not required by FDA regulations, negative breath tests for alcohol constitute an important sign that rehabilitation is under way, and demonstration of consistent negative results is strongly recommended as a criterion for eligibility for take-home medication. The amount of medication dispensed for take-home purposes gradually increases in accordance with program policy and FDA regulations throughout the rehabilitation, supportive care, and medical maintenance phases.

Throughout treatment, providers should monitor patients for stresses or life changes that could lead to relapse. When such stressors are identified or anticipated, more frequent clinic visits, closer monitoring, and increased support often prevent relapse. In such situations, patients who are not required to attend the clinic frequently (such as those on medical maintenance) can continue to receive their take-home medication but may be required to come to the clinic to take it or to receive additional counseling until the crisis passes. In this way, patients retain a sense of control, while providers ensure that medication is not diverted.

In supportive care, the length of time for which take-home medication is dispensed varies according to individual needs but is usually not longer than 6 days. Before a patient is considered for transition into medical maintenance, he or she has generally been receiving take-home medication in supportive care. LAAM, which has a longer duration of action than methadone, may be useful during supportive care or even earlier in treatment to limit take-home medication while maintaining the patient's contact with the clinic. (See the TIP LAAM in the Treatment of Opiate Addiction.)

During tapering of methadone, take-home medication is continued until lower doses are reached. At this point, patients must be seen more frequently and should be required to come to the clinic for each dose. Clinic policies concerning take-home medications during the tapering phase must be tailored to individual needs.

### Hospitalization of Methadone Patients

During a medical crisis requiring hospitalization, it is important for the physician providing methadone treatment to communicate with the hospital attending physician and other members of the healthcare team. The team should be informed of the patient's methadone dosage and the date on which methadone was last received.

It is extremely important that the treating physician be aware that the patient will probably require larger amounts of medication for anesthesia, and that adequate pain relief will require that the patient receive the normal methadone dose (or its equivalent) plus additional medication. Communicating these facts to the healthcare team will usually ensure that appropriate care is administered.

In addition, the healthcare team should be advised to institute appropriate behavioral controls to prevent the patient from using illicit substances while in the hospital. These controls are especially important for unstable methadone patients who are in the acute phase of treatment. They may include limiting visitors, preventing the patient from wandering through the hospital, and scheduling regular urine drug screens. It is usually helpful to provide psychiatric consultation to medical or surgical staff, especially in the case of patients with comorbid psychiatric disorders.

## Conclusions

The use of a phased model of methadone treatment assists patients in setting goals and establishing markers for progress. Each patient's needs, however, rather than the phases themselves, should dictate the specific course of treatment. The phases should simply facilitate the natural course of the recovery process.

This chapter provides a framework for a phased model of treatment that must be adapted to the needs of each patient population and treatment setting. As this model evolves, each component must undergo critical evaluation from the perspective of patient outcome, cost-effectiveness, and quality improvement so that its advantages and shortcomings can be clearly documented.

## Summary of Recommendations

Recommendations of the panel are also summarized in Exhibits 3-2 and 3-3 (see especially the columns headed "Indicators for Transition . . .").

1. Phases of treatment should be established as a dynamic continuum that allows each patient to progress according to his or her individual needs.
2. Treatment outcomes should be evaluated not solely in terms of how many phases the patient has moved through, but rather by the degree to which the patient's needs, goals, and expectations have been met by the treatment program.

### Acute Phase

1. Staff should have frequent interaction with patients, should encourage ongoing dialogue concerning their symptoms, and should not take a punitive approach if drugs other than opioids are being used.
2. Independent psychiatric disorders and substance-induced psychiatric disorders should be identified and addressed.
3. Long-standing medical problems should be addressed immediately. Stabilization of acute conditions and the institution of ongoing care for chronic conditions are mandatory before a patient can move out of the acute phase.
4. Patients' needs for basic necessities such as food, clothing, housing, and safety should be determined and referrals made to appropriate agencies.
5. A patient's legal problems should be addressed as soon as possible after treatment is initiated.
6. The counselor should correct misconceptions about treatment and educate patients about the program and the benefits and goals of treatment.
7. Patients should be introduced to key staff members of the treatment program as early as possible to foster an atmosphere of safety, trust, and familiarity.
8. Waiting times should be minimized to demonstrate that patients' time is valued.
9. Counselors should explore and openly address patients' past negative treatment experiences.

### Rehabilitation Phase

1. The methadone dosage must be stabilized at a comfortable level prior to entering this phase.
2. Efforts should begin toward productive participation in constructive activities such as full- or part-time employment, education, vocational training, childrearing or homemaking, or volunteer work.
3. Information about outside support groups introduced during the acute phase should be periodically reviewed.
4. Providers should cultivate relationships with churches and community groups to provide support and facilities for methadone patients.
5. Providers should help patients develop and maintain coping skills to deal with relapse triggers.
6. Medical care for methadone patients should be identical to that provided for other patients.
7. Educational, literacy, and vocational programs should be provided to help patients build the skills they need to function independently. Information about budgeting personal funds and setting up bank accounts should be included.
8. Providers should help patients gain a stable source of legal income to ensure that they will not resort to criminal activities.
9. Patients should be encouraged to take responsibility for their own legal problems.
10. Patients should be taught coping skills to deal with frustration, anxiety, and boredom.

### Supportive Care Phase

1. Life domains and other issues should continue to be assessed at least quarterly.

### Medical Maintenance Phase

1. Several criteria should be considered in determining eligibility for the medical maintenance phase
  - Number of years in methadone treatment (at least 3 years under current FDA guidelines)
  - Elimination of drug use for at least 1 year
  - Noninterfering alcohol use
  - Stable living conditions in a drug-free environment
  - Source of stable income
  - Involvement in productive activities
  - No criminal or legal involvement for the last 3 years; not on parole or probation
  - Adequate social support system and absence of significant psychiatric problems.

### Tapering and Readjustment Phases

1. Patients' preferences and desires about tapering should be taken into account, with the understanding that they can return to their previous methadone dosage if tapering is not successful.
2. Patients should be strongly encouraged to discuss any difficulties they experience with tapering and readjustment so that appropriate action can be taken if this approach fails and relapse can be prevented.
3. Patients should be instructed about normal withdrawal symptoms and the importance of tolerating them without recourse to opioid use.
4. Emphasis should be placed on reinforcing the patient's coping and relapse prevention skills.
5. Special attention and support should be provided during the first 3 to 12 months following detoxification, when most relapses occur. Support should focus on fostering self-sufficiency and reinforcing the goals of treatment.

It is extremely important that the treating hospital physician be informed that the patient will probably require larger amounts of medication for anesthesia, and that adequate pain relief will require that the patient receive the normal methadone dose (or its equivalent) plus additional medication.

### Transition Between Phases

1. The treatment system must be flexible enough to allow for transition from one phase to another according to the patient's progress.

### Discharge

1. Program rules and the terms under which patients can be involuntarily discharged from the treatment program should be explained clearly to the patient.
2. Staff members should identify problems as they emerge and respond to them promptly.
3. Patients with a history of failed attempts at detoxification who request discharge should be counseled, educated about their risk of relapse, and encouraged to stay.
4. Patients who are using opioids or other illicit drugs should be strongly discouraged from undergoing voluntary detoxification.
5. The discharge plan should allow the patient to reverse the decision at any point. The patient should be given the opportunity to return after discharge, and reentry into the program should be as easy as possible.
6. Involuntary discharges should be made with the understanding that the patient may return to the program, provided that identified preconditions have been met, within a specified period of time.
7. The decision to discharge for drug use should not be made solely on the results of urine testing; rather, a range of factors should be considered.
8. Programs should consider for discharge only those persons judged to be "nonresponders" to methadone treatment despite the best efforts of the staff.
9. Drug-using patients should not be allowed thesame privileges (such as take-home medication) as other patients.
10. Ideally, patients should be readmitted within 30 days to avoid their seeking admission to another program and perpetuating the revolving-door syndrome.
11. For readmitted patients, a complete reintake assessment is probably in order if this period is longer than 1 month but is probably not necessary if the patient has had a shorter absence from treatment.
12. Opioid substitution therapy programs should have written guidelines under which cases of involuntary discharge may be appealed and examined by staff.

### Hospitalization

1. During a medical crisis requiring hospitalization, it is important for the physician providing methadone treatment to communicate with the hospital attending physician and other members of the healthcare team.
2. It is important to communicate to the treating physician that the patient should continue to receive his or her normal methadone dose, plus additional medication for pain relief.