# Chapter 1 -- Patient Matching: Historical Perspective and Overview

The purpose of this Treatment Improvement Protocol (TIP) is to develop guidelines to assess the needs of patients in opioid substitution therapy and to match patients, based on their needs, to a variety of services, including medical, psychiatric, social, and other support services. Several studies show that patients who receive the services they need are more likely than others to stay in treatment and to have positive outcomes. The concept of matching patients to services according to their needs is widely accepted in other medical treatment settings but until recently was not used in the field of opioid substitution therapy. This TIP details the current knowledge about patient matching in opioid substitution therapy; its goal is to help programs more fully develop the important aspects of treatment that derive from matching strategies.

Another TIP in this series, State Methadone Treatment Guidelines, presents a structure for States to follow to comply with Federal regulations when providing methadone treatment (the most common form of opioid substitution therapy). The methadone document describes the best treatment practices in separate chapters on admissions procedures, dose determination, use of urinalysis as a clinical tool, take-home medication, and patient retention. The methadone guidelines discuss the provision of methadone treatment to pregnant women, multiple substance abusers, and persons with human immunodeficiency virus/acquired immune deficiency syndrome (HIV/AIDS) and other infectious diseases. The TIP on methadone also discusses matching strategies.

The current TIP focuses on ways to develop matching strategies on a comprehensive, programmatic level. This TIP and the previous one provide useful information about the best practices for providing opioid substitution therapy and about how to improve patients' chances for recovery by matching services to patient needs.

This document on patient matching continues the efforts of the Center for Substance Abuse Treatment (CSAT) to ensure that opioid substitution therapy programs throughout the United States provide high-quality, cost-effective services. Two other TIPs LAAM in the Treatment of Opiate Addiction and Assessment and Treatment of Cocaine-Abusing Methadone- Maintained Patients provide information on delivering the highest quality and most cost-effective treatments to the broadest range of persons with opiate dependence.

In addition, this TIP on patient matching describes a further evolution of opioid substitution therapy as an effective treatment. The epidemics of AIDS and tuberculosis (TB) and the advent of managed care have a strong influence on opioid substitution therapy programs. These epidemics make it more important than ever that programs find ways to address the wide range of patient needs, retain patients in treatment, and use resources efficiently. Patient matching is a critical strategy in attaining these goals.

In recent years, phased treatment models have been developed to help planners and providers better conceptualize opioid substitution therapy to improve service delivery and resource allocation. This document presents a six-phase treatment model, which includes an initial evaluation and an ongoing assessment of progress; it describes patient treatment needs during each phase and the types of services that can best meet these needs. Since effective patient matching depends on careful ongoing assessment, this TIP outlines the assessment process and describes clinical indicators for transition to other treatment phases. It also reviews treatment elements, including a core group of treatment and support services and a variety of counseling and therapeutic services that will enable opioid substitution therapy programs to meet patient needs via matching strategies.

Also addressed are the issues of program self-evaluation and cost-benefit analysis to help programs stay responsive to the realities of managed care and to provide input into managed-care policies and decisions.

## Managed Care and Opioid Substitution Therapy

Managed care is an evolving process that was first developed in the private sector, mainly for individuals who are regularly employed. It was only recently applied to the public sector and to opioid substitution therapy programs. Many States are moving toward the use of a managed care model to provide healthcare services to Medicaid patients. The public sector, especially substitution programs, has large numbers of chronically ill and disadvantaged persons with multiple problems. Persons with multiple and chronic problems present a special dilemma for managed care programs, which traditionally focus on achieving cost savings by reducing or denying services. This strategy may be cost effective when applied to relatively healthy persons with illnesses that are usually time limited; it may be counterproductive if applied unwisely to opioid substitution therapy, which is a long-term process.

On the other hand, the managed care approach has considerable potential to facilitate treatment matching within opioid substitution therapy programs, provided that the managed care entity is held responsible for treating the medical, psychiatric, family, social, and other problems of patients in the program's care. When managed care organizations attempt to help the patient to obtain the most cost-effective medical, psychiatric, and other services for opioid substitution therapy, they do so within the opioid substitution programs. Emergency psychiatric and medical hospitalizations can be reduced when appropriate outpatient treatment and preventive services are provided to persons who are high users of inpatient treatment.

Thus, managed care, rather than being regarded as a nemesis for opioid substitution therapy, can be seen as having the potential to support this treatment, especially in regard to developing effective matching strategies. The reasons are financial. Very high costs result when patients are hospitalized. Most opioid-dependent patients are potential frequent users of hospital beds -- for detoxification or for psychiatric, medical, surgical, or other conditions that may or may not be related to their substance use disorder. It is most cost effective to prevent hospitalization (including emergency room use) by ensuring that opioid substitution therapy programs have the professional resources necessary to develop effective psychiatric, medical, and other matching strategies.

Many of the services described in this TIP have not been routinely available to most substitution therapy programs. However, they may become more available when managed care organizations fully realize the cost savings that can be achieved by using matching strategies and outpatient professional services to prevent hospitalization and other more expensive treatments. If this view is held, managed care could help opioid substitution therapy programs to become the backbone of an effective outpatient, medical, and psychiatric treatment delivery system, which functions to reduce overall health costs for a group of patients who are high users of expensive inpatient services.

Although the managed care approach may be cost effective when applied to relatively healthy persons with time-limited illnesses, it has a great potential to be extremely counterproductive if applied to long-term therapy.

Many States currently lack a model to assess the appropriateness of treatment levels and patient matching in opioid substitution therapy programs. Models could be based on those being considered for treatment of other chronic diseases, such as HIV infection, that recognize the chronic nature of the condition and the need for extended therapy. It is very important that opioid substitution therapy programs work with managed care companies to establish assessment and treatment guidelines that are both cost effective and that match the needs of the patients.

## Patient Matching

Patient matching is the process of individualizing treatment resources to patient needs and preferences. It requires an assessment of the extent, nature, and duration of the individual's alcohol and other drug (AOD) use and treatment history, as well as an assessment of medical, psychiatric, and psychosocial needs and functional status. The patient's gender, culture, ethnicity, sexual orientation, and language are of key importance. Matching is a participatory activity that involves both the clinician and the patient. Also important is the patient's motivation as well as the level of support available to the patient to achieve and maintain a life-style free of AOD abuse.

Most patients who require opioid substitution therapy have long-term, chronic addiction ailments that cause serious problems in many life areas. Patient matching should be undertaken with the understanding that many persons who are addicted to opioids have multiple needs. Because of the complexity of patients' needs and the scope of services required, matching is best accomplished through a three-step process that involves 1) assessing, 2) selecting the most suitable treatment modality and site, and 3) identifying the most appropriate ancillary services.

An individualized treatment plan with well-defined short- and long-term goals is the product of the patient-matching process. This plan is reevaluated at regular intervals to determine if it should be modified in respect to new issues that may arise as earlier identified problems are resolved.

### Advantages of Patient Matching

Data from matching studies have become available only within the last 10 to 15 years, and thus the subject of this TIP is relatively new. In addition, the available data address relatively few of the many areas that could be investigated in this complex subject. However, the available data indicate that matching increases the likelihood of positive treatment outcomes. Provision of individualized, comprehensive services were shown to increase rates of retention in treatment (Condelli, 1993; Joe et al., 1991); the longer a patient is in treatment, the better the chances for recovery.

Matching also improves resource allocation by ensuring that patients receive the appropriate level and type of services. It ensures appropriate use of the specific training and experience of all members of the multidisciplinary clinical team, thereby increasing the quality of care as well as team members' job satisfaction. The short-term cost of providing individualized, professionalized services may be higher than that of providing more limited care. However, the ultimate cost to the healthcare system and to society, as measured in terms of increased productivity and reduction in criminal activity, is likely to be greatly reduced.

### The Need for Patient Matching Guidelines

The idea of patient matching, while not new, has become more attractive in the wake of pressures to contain the overall cost of healthcare, particularly if matching in an outpatient setting can reduce the need for hospitalization. Nonetheless, the concept of matching is as methodologically elusive to researchers as it is attractive to clinicians (McLellan and Alterman, 1991), and many of the basic concepts of patient matching have not yet been clearly defined or fully accepted. As additional data becomes available, these problems may be resolved.

The services that are described in this TIP may become more available when managed care organizations fully realize the cost savings that can be achieved by using matching strategies and outpatient professional services.

One example of the early development of the concept of patient matching within the substance abuse treatment field is that, despite the existence of detailed Federal and State regulations, methadone treatment services and outcomes vary dramatically from program to program (Ball and Ross, 1991; General Accounting Office, 1990). Some programs are still basing patient management decisions on outdated clinical paradigms that are not consistent with current research findings. For example, many programs administer low dosages of methadone (i.e., 25-40 mg as the average) in the belief that lower is better, despite the abundant research supporting the efficacy of higher dosages (60 mg or more), with dosage levels individualized for each patient. Further, some programs encourage time-limited treatment rather than long-term substitution therapy. In these cases, clinical practice does not reflect research findings that demonstrate the efficacy of higher doses and long-term, very extended, or even indefinite treatment.

In other cases, State regulations prohibit the use of methadone in settings and modalities that are an important part of treatment matching and the continuum of care. For example, consider the case of a homeless patient who might do well on substitution therapy if he or she had a stable living arrangement; however, the housing or shelter that could provide such an arrangement does not admit persons on methadone. Another example is the case of a methadone-maintained patient who needs brief hospitalization for medically supervised withdrawal (detoxification) from another substance, but the detoxification program does not allow the patient to be maintained on methadone during the process.

This TIP describes the problems and points out rules that need attention and revision. As a result, it is hoped that some regulations will be modified to become more consistent with an integrated, comprehensive system of treatment that includes patient matching within a continuum of care.

The lack of resources and staff to provide an appropriate range of services is an impediment to developing matching strategies within the current AOD, health, psychiatric, and social service systems. There is a tendency in some programs to wall off substance abuse treatment from other services, as if to say, "We are responsible only for the substance use disorder and nothing else." This type of organizational structure is a significant obstacle to the use of effective matching strategies and often inconveniences the patient to the point that he or she does not comply with important treatment recommendations. In addition, it runs counter to AOD provider's growing awareness of the need to develop increasingly effective systems of primary care that treat the whole person.

Regulations in some States prohibit the use of methadone in settings and modalities that are an important part of treatment matching and the continuum of care.

It is not necessary for each program to offer the full spectrum of needed resources and services to successfully apply patient-matching techniques. Through staff training and the use of carefully developed referral networks supported by appropriate guidelines, staff can identify the need for additional services and work with patients to offer them access to services that a single program is unable to provide. Psychiatric, medical, and social work services are the most commonly needed and used. Programs should place the highest priority on obtaining resources or developing relationships with providers that can provide these services in a convenient and cost-effective manner.

The remainder of this chapter provides a historical review of the development of opioid substitution therapy and ongoing treatment issues. HIV/AIDS and the concept of harm reduction are discussed, and additional comments about the impact of managed care on the delivery of substitution therapy are reviewed.

## Historical Perspective

When new treatments are developed, matching patients to these treatments can be done relatively quickly. Clinicians in most medical settings readily accept the concept of matching. There are numerous examples of this phenomenon. For instance, clinicians began using a combination of drugs to treat HIV infection when it was found that the HIV virus was able to quickly develop resistance to AZT when it was used alone (Cheesman et al., 1994).

However, in the case of opioid substitution therapy, the progression from the development of a treatment for a very serious disorder to further treatment refinements, including the use of matching strategies, has been delayed. For example, many single State agencies have been slow to approve use of the opioid substitute levo-alpha-acetyl-methadol (LAAM), even though its use reduces the risk of diversion. In addition, although methadone has now been used for almost 30 years, patient-treatment matching strategies have only just begun to be formally addressed in opioid substitution therapy programs.

Reasons for this halting progression may be found in the historical development of substitution therapy and in the ambivalence that has always surrounded its use. Treatment of opioid dependence with substitution therapy has been tried in isolated cases by individual practitioners and applied on a larger scale as part of organized treatment programs for at least 100 years. Until the advent of methadone maintenance in the 1960s, there was little or no scientific evidence that opioid substitution therapy was generally helpful. Perhaps because of this lack of evidence, reports of improper use, and diversion of legally prescribed opioids, substitution therapy fell into public disrepute during the 1920s.

An administrative structure to control prescription and consumption of addictive substances was put into place by the Harrison Act of 1914, which required dispensers of opioids and cocaine to register annually, to pay a fee, and to use special forms provided by the Internal Revenue Service. This move toward more controls on addictive substances was consistent with the temperance movement and the enactment of Prohibition in 1919. These structures to introduce controls over prescribing, though seemingly modest in scope, were interpreted by law enforcement agencies in increasingly restrictive ways beginning in the 1920s. As a result, the few physicians who continued to prescribe opioids to addicted persons were forced to discontinue this practice; to do so, even in the absence of diversion or overt criminal behavior, became defined as an illegal act that could result in suspension of a physician's medical license or even a prison sentence.

This movement toward strict limits on prescribing was greatly strengthened under the leadership of Harry Anslinger, who was commissioner of the Federal Bureau of Narcotics (FBN) from 1930 to 1964. (The FBN became the Drug Enforcement Administration [DEA] in 1973.) Treatment became totally abstinence oriented, and two Federal hospitals with long-term residential settings were established during the 1930s to treat opiate-addicted individuals. One hospital was at Lexington, Kentucky, and the other at Fort Worth, Texas. Each hospital accepted voluntary patients as well as prisoners who had been convicted of Federal crimes that were often related to opiate dependence. Much of the early research on opioid dependence was conducted in these settings, especially the Lexington facility. These treatment facilities were very small and required patients to remain for long periods in residential therapy. In addition, they were expensive, and although patients improved, relapse rates were high after discharge from the residential setting.

Treatment of opiate dependence with substitution therapy has been tried in isolated cases by individual practitioners and applied on a larger scale as part of organized treatment programs for at least 100 years. With the advent of methadone maintenance studies in the 1960s, scientific evidence established that opioid substitution therapy is often effective.

In the early 1960s, Drs. Marie Nyswander and Vincent Dole became interested in opioid addiction and relapse. They were aware of the problems that had been associated with previous attempts at substitution therapy but did not give up on the idea. They began to examine methadone as a possible solution. This drug had been developed during World War II by Germany when its opiate supplies were interrupted by the war. Methadone has all the pharmacological effects of other opioids; however, it also has two properties which make it potentially useful for substitution therapy: 1) It is well absorbed when given orally, and 2) it suppresses opioid withdrawal symptoms for 24 to 36 hours.

Thus, a single oral dose of methadone can prevent opiate withdrawal symptoms for a day, while also avoiding the complications associated with parenteral use. Using high doses of methadone for substitution therapy was found to produce significant cross-tolerance to illicit opiate, thus diminishing the high produced by heroin, which further contributed to methadone's efficacy. In addition, methadone provides much more control over diversion or improper use, since a single daily dose can be administered under direct observation.

Dole and Nyswander began a series of experiments in which they selected persons with a long history of opioid dependence who were free of serious medical or psychiatric problems and who were willing to participate in a study of methadone substitution therapy (Dole and Nyswander, 1966; 1967). Careful followup showed a significant change in the behavior that had been typical of these patients. Illicit heroin use and criminal behavior were markedly reduced, patients' sense of well-being and self-respect were significantly improved, employment increased, and family problems were improved. In addition, medical evaluations demonstrated no significant adverse effects as a consequence of long-term maintenance (Kreek, 1973; 1978; 1983). On the basis of these early and very positive results, methadone was approved in the early 1970s by the Food and Drug Administration (FDA) as a substitution therapy for chronic opioid users who had demonstrated an inability to achieve sustained abstinence.

### Change in Public Policy

Thus, after more than 50 years of public and legal opposition to substitution therapy, a new drug, methadone, had been studied, applied, and found effective. Within a period of several years, almost 100,000 opioid-addicted persons were being treated with methadone in the United States. Methadone maintenance became and remains the single treatment that is most acceptable to opiate-addicted individuals.

This marked change in policy occurred rapidly and was not without its opponents, especially among law enforcement agencies that had played a significant role in implementing the earlier restrictive policies. Some medical professionals, particularly those committed to long-term drug-free treatment, also opposed its use as did some lay persons and politicians who felt that it represented "giving in" to the problem or that it was another form of "slavery." These factors contributed to a lack of public and professional acceptance of opioid substitution therapy. In fact, attempts were made to arrest Dr. Dole, even after he reported the very positive results that could be achieved by methadone maintenance treatment.

Perhaps as a result of the legal and political ambivalence surrounding methadone maintenance, a large number of studies were done to confirm its efficacy (Ball and Ross, 1991; Dole and Joseph, 1978; Dole and Nyswander, 1967; Dole et al., 1966; Gearing and Schweitzer, 1974; Gerstein and Hartwood, 1990; Hartel et al., 1988; Kreek, 1983). Though few found results as dramatic as those of the early studies of Dole and Nyswander, almost all studies confirmed the original findings: marked reductions in opioid use and crime and improvement in employment and overall social adjustment.

## Federal Regulations and Public Policy

### The Need for Regulations

Since methadone can be abused like any other opioid, regulations were developed by States, FDA, and DEA to limit and control its use. These regulations govern who can administer methadone maintenance, eligibility for treatment, evaluation procedures, dosages, take-home medications, frequency of patient visits, medical and psychiatric services, counseling, support services, and related details. The various regulations are complex, and State regulations are not always identical to FDA regulations. For example, Federal regulations do not specify a limit on time in treatment; however, some States and some programs set such limits. Similarly, some States limit dosages of methadone to 80 mg a day or less, a lower limit than is permitted by Federal regulations.

The FDA regulations were enacted in 1973 and revised in 1980 and 1989; they have been described in detail in a previous TIP State Methadone Treatment Guidelines. Copies of the most current FDA regulations are included in appendices to that document.

The FDA has responsibility for approving programs and ensuring compliance with FDA regulations; the DEA monitors the security of program facilities and compliance with regulations concerning the handling of controlled substances. Programs must also receive approval from the State methadone authority, which monitors the same areas as the FDA and the DEA, and also serves as a source of technical assistance. In addition, methadone treatment programs must meet other requirements to be accredited by the Joint Commission on Accreditation of Healthcare Organizations (JCAHO) and the Commission on Accreditation of Rehabilitation Facilities (CARF), if they choose to be certified by these agencies.

### Influence of Regulations on Developing Matching Strategies

The emphasis on regulatory compliance that has dominated opioid substitution therapy programs since their inception has probably inhibited the development of patient-treatment matching strategies. Although it is probably necessary to have a clinically informed set of regulations that are reasonably enforced by qualified and well-trained persons (characteristics that have not always been the case [Institute of Medicine, 1995]), the regulatory emphasis has consumed so much of treatment providers' energy that it has in all likelihood diverted attention from more clinically focused activities and impaired the development of clinically focused approaches, such as matching strategies and treatment guidelines.

An emphasis on regulatory controls may have been necessary when opioid substitution therapy was first developed. However, the relevance of a regulatory emphasis at the present time is not so clear. For example, a recent report on methadone by the Institute of Medicine concluded that the emphasis on regulations has focused too much on protecting society from methadone and not enough on developing methadone programs to best help persons with opioid dependence and to protect society from the social disruption caused by heroin addiction (Institute of Medicine, 1995).

The potentially adverse effects of an overemphasis on regulatory control may be strongest in the area of patient-treatment matching. The original patients selected by Dole and Nyswander for substitution therapy were generally not polydrug abusers; they were free of serious medical or psychiatric problems. After methadone was approved for general use, a much more heterogeneous group of patients, in particular those with serious psychiatric and medical problems, was admitted to treatment. These patients did not progress as well as the original treatment group (McLellan et al., 1983b).

The number of multiplicatively impaired patients has been growing, especially since the AIDS epidemic. Patients with medical and psychiatric impairments are those who can best be served by treatment matching strategies; they usually do not progress unless these approaches are instituted. An emphasis on regulatory compliance or overly restrictive interpretation of existing regulations can impair the development of matching strategies and reduce the chances of good treatment outcomes for patients with multiple problems.

## LAAM

LAAM is a long-acting opioid that can be used in place of methadone for opioid substitution therapy. It was approved by the FDA in July 1994, after two decades of study. Its effects are similar to those of methadone; that is, it creates a pharmacologic cross-tolerance to heroin and other opioids and therefore blocks the euphoric effects of those drugs while also controlling craving. LAAM can suppress the signs and symptoms of opiate withdrawal for 48 to 72 hours, whereas methadone is effective for 24 to 36 hours.

A 1995 report on methadone by the Institute of Medicine concluded that the emphasis on regulations has focused too much on protecting society from methadone and not enough on developing methadone programs to best help persons with opioid dependence and to protect society from the social disruption caused by heroin addiction.

Use of LAAM allows patients to visit the clinic less frequently; instead of daily visits for methadone, LAAM can be administered every other day from the beginning of treatment. In addition, some patients report that they feel better on LAAM than on methadone, perhaps because of LAAM's longer duration of action. Some patients have reported a "smoother" effect, with fewer ups and downs.

LAAM is an alternative to methadone for opioid substitution therapy; it allows the patient and clinician another choice. Although LAAM has been approved by the FDA, it must also be approved by the individual State in which it is to be used. As of this writing, approximately 20 States have approved the use of LAAM, and it is being used in Portugal and several other European countries.

LAAM is discussed in detail in another TIP in this series, LAAM in the Treatment of Opiate Addiction.

## Treatment Issues

Since opioid substitution therapy became widespread, some important treatment issues have come into focus. Several of these issues have a direct bearing on the ability of programs to effectively carry out patient-treatment matching. Two of the most important issues involve questions about the most effective methadone dose and the optimal level of psychosocial services to provide in substitution therapy programs. Other issues relate to the problems of polydrug abuse and to choosing the best approaches for treating dually diagnosed patients, dispensing take-home medications, and managing behavioral problems in the immediate vicinity of the methadone clinic facility.

Several studies have been done to explore the issues of dose, psychosocial services, and management of dually diagnosed patients. Studies of dose have shown conclusively that, although some patients do well on 30 to 50 mg per day, those on higher doses (60 mg per day or more) generally do better (Ball and Ross, 1991). One of the best designed of these studies was done by Ling and associates in the Veterans Administration (Ling et al., 1976). It showed that patients randomly assigned to receive 100 mg of methadone a day did significantly better than those receiving 50 mg a day. The more positive effects of higher doses are probably mainly a result of the significant levels of cross-tolerance that are obtained.

Other studies have addressed questions regarding the most appropriate levels of psychosocial services and the treatment of dually diagnosed patients. One of the most consistent findings of these studies is that there is no single predictor of success for patients in treatment. Some have problems only with substance abuse, while others have many problems, including psychiatric, legal, medical, family-social, and employment problems. Studies have usually found that the provision of more services is associated with better treatment outcomes. Studies that have more closely examined interactions between services and outcomes have found that patients are usually helped when services are targeted to specifically identified problems (McLellan et al., 1993). For example, studies have shown that professional psychotherapy given in addition to drug-focused paraprofessional counseling can improve outcomes of patients with recurrent and coexisting psychiatric symptoms (Woody et al., 1991).

Ambivalence about opioid substitution therapy continues in spite of the overwhelming scientific evidence of its effectiveness. Many people are uncomfortable maintaining patients on methadone for long periods, especially when maintenance may be indefinite. Some of the controversial issues focus on very real problems such as how best to treat methadone-maintained patients who abuse or are dependent on other drugs. Some programs want to withdraw from methadone those patients who have other AOD problems or serious medical or psychiatric problems. Use of cocaine, benzodiazepines, and alcohol has presented special difficulties, since administration of methadone does not directly address the use of these substances. Evidence is accumulating, however, that the psychosocial and behavioral aspects of methadone treatment programs are often helpful in suppressing nonopioid drug abuse (Arndt, 1992; McLellan et al. 1993) however, psychosocial treatments alone leave much room for improvement.

Other issues sometimes focus on the goals of methadone treatment. Should methadone maintenance be a stepping stone to eventual abstinence, or is it an acceptable lifelong treatment? From the data, one could argue that it is an acceptable lifelong treatment for many patients but that some can achieve long-term and stable drug-free adjustment. Who are these patients, and how are they best identified? These questions need further research.

A current and important issue, and one on which little research data are available, is how to decide that methadone treatment either is appropriate for a patient or is not working. Studies indicate that overall drug use by most methadone patients is markedly reduced, even though total abstinence may not be achieved. Although the goal of most treatment providers is to maintain patients on methadone in the absence of illicit drug use, this goal is often not achieved. At what level of drug use does one conclude that methadone maintenance is not helping and another treatment should be tried, even to the point of terminating methadone treatment against the patient's wishes?

Ambivalence about opioid substitution therapy continues in spite of the overwhelming scientific evidence of its effectiveness. Many people are uncomfortable maintaining patients on methadone for long periods, especially when maintenance may be indefinite.

Decisions in this area have always been difficult, but they have become even more complex with the advent of HIV infection. As discussed later in this chapter, data are accumulating showing that opioid-addicted persons who are maintained on methadone have a substantially reduced chance of becoming infected with HIV, even though they might not completely stop illicit drug use (Metzger et al., 1993). At what point can it be said that enough harm reduction has occurred to justify continued methadone maintenance despite the fact that the patient's progress is not at the expected level? More data are needed to guide decisions in this area. Available data indicate that substantial risk reduction can occur without the achievement of total abstinence. However, patients who continue to use drugs may erode clinic morale as other patients come to the conclusion that compliance and abstinence are not expected.

In summary, although many important issues remain, the data strongly indicate that opioid substitution therapy can provide substantial benefits to persons with opioid dependence. This important point should not be obscured in our attempts to identify problems and improve upon methadone treatment, to find newer substitution therapies that may be more efficacious for some patients than methadone, such as LAAM, and to develop guidelines and strategies for treating addicted patients with opioid substitution therapy.

## HIV/AIDS and Harm Reduction

As discussed earlier, there is growing evidence that involvement in opioid substitution therapy reduces the risk of HIV infection, even if illicit drug use is not completely eliminated. In addition, HIV-positive patients who are receiving substitution therapy are engaged in a treatment program in which they are seen frequently. Their engagement in treatment generally allows them better access to important medical services than they might otherwise have (provided the services are available). Engaging this patient population in continued care has significant public health implications. Not only can these patients receive treatment for HIV disease and its complications, but they also can receive counseling about the disease and about behavioral changes that will reduce the risk of HIV transmission.

A prime example of a public health benefit that can be achieved by effectively run opioid substitution therapy programs is screening for tuberculosis (TB), which has increased significantly in recent years, especially in association with HIV disease. The medical evaluations that occur at intake to substitution therapy programs provide an opportunity to identify patients who carry TB or have active TB. One of the difficulties of treating TB is that many persons fail to comply with medication regimens and must be carefully monitored. The frequent clinic visits that are part of opioid substitution therapy provide an opportunity for direct observation of antituberculosis pharmacotherapy.

A more recent harm reduction intervention is interim substitution therapy. This treatment involves daily administration of methadone without provision of regular counseling services. It is applicable only on a time-limited basis and only when there are waiting lists for methadone programs. The aim of interim therapy is to provide some reduction in opiate use while a patient is waiting for a place to open in a more fully staffed treatment program. Interim treatment has been found to decrease the use of heroin and other opioids; however, patients who participate in programs in which more comprehensive services are available achieve greater reductions in use (Yancovitz et al., 1991; McLellan, 1993).

Concerns about interim therapy have been raised, especially if it is seen by providers and managed care companies as a less expensive and equally effective model for the treatment of opiate dependence. Interim therapy should never be viewed as an alternative to comprehensive opioid substitution therapy programs.

Engaging this patient population in continued care has significant public health implications. Not only can these patients receive treatment for HIV disease and its complications, but they also can receive counseling about the disease and about behavioral changes that will reduce the risk of HIV transmission.

## The Need for Resources

Meeting patients' needs in opioid substitution therapy cannot be addressed without looking at the cost benefits of providing comprehensive services to opioid-dependent patients. These are often persons with no readily available entry point into the healthcare system, and methadone treatment programs often provide an entry. Therefore, appropriate decisions about what services are needed, for how long, and in what setting are crucial. As described above, untreated addicted patients meet their healthcare needs in a crisis-oriented episodic fashion -- by utilizing emergency services as their primary care provider. Implementation of comprehensive outpatient models providing long-term care decreases the high utilization of more expensive acute care services.

Many programs are not able to afford comprehensive services for patients entering opioid substitution therapy. Therefore, programs must develop other models for effective services. One option is to develop linkages or networks between services and to refer patients to offsite services, thus attempting to contain costs while providing necessary services. Unfortunately, because of the fragmented system of publicly funded healthcare, public ambivalence about treating persons with opioid dependence, and extremely restricted resources in the public outpatient treatment area, many programs have great difficulty or even find it impossible to establish these liaisons. In these cases, programs must do the best they can and hope for improvements in service delivery that will make meaningful, comprehensive treatment possible.

As discussed earlier in this chapter, the potential financial advantages to managed care companies from combining psychiatric and medical services with substance abuse treatment may change this situation. Treatment providers and taxpayers could benefit from serious efforts to combine these important services and realize the cost savings that may result.

Recent Federal block grant requirements have created a mandatory link between the provision of substance abuse treatment and other healthcare services for pregnant and parenting women, persons from minority groups, individuals with dual diagnoses, injection drug users, disabled persons, HIV-infected persons, and persons with TB. While not designed specifically for opioid substitution therapy, these requirements must be met by all programs receiving Federal funding under the State block grant mechanisms. Now being implemented, the regulations are particularly important for State AOD directors who must determine how to establish the mandated links. These requirements may encourage States, HMOs, managed care companies, and other healthcare providers to increase their efforts to develop the treatment resources that will make matching strategies more of a reality than they are at present. Many of these aims can be achieved through networking.

## Examples of Networking

Effective networking should cut across several disciplines. Some examples of networking are described below:

- Contact with State and city public health, mental health, and vocational rehabilitation departments.
- Creation of ad hoc alliances. For example, under the Yale/New Haven Model, a methadone treatment program became allied with the mayor's task force to create a women's health consortium. The consortium established a referral network through which each client had two counselors, one for methadone treatment and one for other health, mental health, and ancillary needs.
- Access to services supported by the Federal Government, including clearinghouses, electronic databases, and training and technical assistance programs.
- Access to programs for special populations, including abused children, victims of domestic violence, the homeless, and persons with disabilities.
- Use of pro bono legal services.
- Establishment of relationships with health, mental health, and civil rights advocacy groups.
- Use of educational, training, and technical assistance resources available through professional organizations.

Equally important is the development of a proactive attitude toward community outreach. For example, program staff might seek opportunities to sit on the boards of directors of other agencies and organizations, and members of these organizations might be invited to join the opioid substitution program board. Such relationships broaden understanding of individual and shared program goals and increase the likelihood of appropriate referrals. Given the multiplicity of patient needs and limited resources, "turfism" and insularity are ill advised.

In addition to providing concrete services, networking can create a feeling of shared responsibility for patient welfare. It also increases program visibility and broadens public understanding of the purpose of opioid substitution therapy and its role in substance abuse treatment and rehabilitation.

## Optimizing Methadone Treatment Outcome: The Challenges

Persons who are addicted to opioids share many of the problems and needs of those with other substance use disorders. At the same time, opioid-addicted persons present unique treatment challenges. The CSAT consensus panel believes that the following five challenges are especially important.

### Challenge 1: Understanding That Opiate Addiction Is a Chronic, Relapsing Disorder

Among the most important factors to be understood when assessing the progress of an opioid-addicted patient is the probability of relapse, or recurrence of opioid use. Posttreatment followup studies have shown that roughly 80 percent of all patients resume daily use of opioids within the first year of leaving treatment (Ball and Ross, 1991; Hubbard and Marsden, 1986; Simpson and Marsh, 1986). However, it has also been shown that relapses may lead to a series of readmissions that are eventually associated with successive reductions in drug use and even extended periods of remission (Simpson and Savage, 1980). A 12-year followup study of 490 opioid-addicted patients treated in the Drug Abuse Reporting Program showed that each patient averaged more than six AOD treatment admissions. However, improvement occurred over time, and only one patient in four was still using opiates in the year preceding the last followup interview (Marsh et al., 1990).

Even patients who are highly motivated to achieve total abstinence and who terminate treatment under the best of circumstances have a less than 50 percent chance of remaining in full remission for as long as 3 years (Hargreaves, 1983). Such surveys substantiate the General Accounting Office conclusion that heroin addiction is a chronic, relapsing condition that many persons "will battle the rest of their lives" (General Accounting Office, 1990).

Relapses are, in other words, a predictable part of opioid addiction. The number of relapses does not predict failure in treatment; in fact, past relapses correlate positively with ultimate treatment success, and resistance to relapse increases as long-term abstinence increases (Simpson and Marsh, 1986).

Studies that explore additional predictors of treatment outcome have shown that patients who are older, have a stable family and an intact marriage, and are employed are more likely to have positive results than younger, unemployed patients with less stable family support.

Polydrug and alcohol abuse, psychopathology, and a history of criminal activity that is independent of the substance use disorder are associated with poorer treatment outcomes (Anglin and Hser, 1990; McLellan, 1986).

### Challenge 2: Providing Comprehensive Services to Ensure Successful Opioid Substitution Therapy

Substitution therapy often has been mistakenly perceived as a simple and inexpensive pharmacologic treatment for opioid addiction. On the contrary, most patients who enter opioid substitution therapy have multiple needs and the most effective programs provide comprehensive services to meet these needs (Anglin and Hser, 1990; Ball and Ross, 1991; Joe et al., 1991). One recent study has shown that 85 percent of patients entering methadone treatment had problems in more than one of the following areas: physical or mental health; family and peer relationships; and legal, educational, vocational, and financial matters.

Unfortunately, because of 1) the fragmented system of publicly-funded healthcare, 2) public ambivalence about treating persons with opioid dependence, and 3) extremely restricted resources in the public outpatient treatment area, many programs have great difficulty or even find it impossible to establish liaisons with other agencies to provide needed services.

Although most patients' needs were in more than one of these areas, only 25 percent reported receiving any medical, psychiatric, or social services during the critical first month of treatment (Condelli, 1993). The role of ancillary services in improving treatment outcome is illustrated in studies such as that of McLellan et al. (1993), who documented an improvement in AOD treatment outcomes associated with provision of appropriate psychosocial services to methadone patients. As discussed in later chapters of this TIP, some patients require assistance in gaining access to and utilizing needed services. An addictions counselor or case manager often performs this function.

### Challenge 3: Engaging and Retaining the Patient in Treatment

Length of time in treatment is one of the most consistent indicators of positive treatment outcomes. It has repeatedly been shown to be associated with reduced use of opioids and other drugs, greater productivity, and reduced criminal activity (Ball and Ross, 1991; D'Aunno and Vaughn, 1992; General Accounting Office, 1990; Simpson and Sells, 1982). A minimum of 3 months in treatment is usually necessary before progress toward recovery begins (Simpson and Sells, 1982).

Retention is thus a primary objective of treatment, and the challenge to the clinical team is to take every reasonable action to keep the patient actively engaged. Several investigators have sought to determine the factors most likely to be associated with retention. Among these are comprehensive and individualized services, caring staff, "user friendly" program protocols, and an adequate methadone dosage (Condelli, 1993; Joe et al., 1991).

To promote retention, patients should be engaged in treatment and participate actively in the therapeutic process. More frequent attendance, compliance with psychiatric services, and use of other ancillary services are associated with improved treatment outcomes (McLellan et al., 1993; Simpson et al., 1995). Thus, augmenting program resources and encouraging their use should be prime concerns of program staff. One recent study found that elimination of treatment fees increased retention during the first year of treatment (Maddux et al., 1994). Consideration also should be given to developing techniques for monitoring service delivery and levels of patient engagement over time (see Chapter 5 on program evaluation). As is discussed later in this TIP, case managers can play an important role in retaining patients in treatment by ensuring that they gain access to and use needed services.

Factors most likely to be associated with retention in treatment are comprehensive and individualized services, caring staff, "user friendly" program protocols, and an adequate methadone dosage.

### Challenge 4: Managing Patient Noncompliance in a Positive Manner

Recent research has deepened understanding of the contribution of patient motivation and readiness for change to positive outcome in persons with AOD disorders (Miller and Rollnick, 1991; Prochaska and DiClemente, 1986). For this reason, it is important to explore patient motivation at the time of assessment and throughout treatment. Most patients are initially ambivalent about treatment, and clinicians must help them resolve this ambivalence. Many patients may have attitudes or experiences that create obstacles to engaging in treatment. For example, some patients have the fixed notion that only methadone will work for them and that methadone is all they need. Others may not want to participate in 12-step programs because of negative past experiences with persons in those programs who rejected opioid substitution therapy. Some patients may resist medical care because healthcare providers in the past have reacted negatively to their addiction and its associated behavior.

Clinicians must be prepared to identify and overcome these obstacles. They also must be prepared to clarify and negotiate mutually acceptable treatment goals. The more committed patients are to their treatment goals, the more likely they are to remain in the program and have a positive outcome (Simpson and Joe, 1993).

Patient noncompliance -- whether it manifests as a deviation from an individual treatment plan or as a violation of program rules -- should be seen not only as a sign of potentially poor outcome, but also as an indication of possible problems in the treatment plan. Providers should continually review and examine their delivery of services before "blaming" the patient for not complying with treatment. Program staff must be alert to subtle attitudinal changes of patients and be prepared to address those attitudes even before problems stemming from noncompliance arise and interfere with treatment. The reasons underlying a loss of motivation or ambivalence about treatment goals should be promptly explored and resolved, if possible, with the objective of making the treatment plan more realistic. For example, a patient's response to a brief relapse to opioid use could lead to discouragement and premature termination if the staff did not encourage and educate the patient about the realistic course of addiction treatment.

### Challenge 5: Expanding Community Awareness of the Purpose and Outcome of Opioid Substitution Therapy

Clinicians who provide opioid substitution therapy must create opportunities to educate the community, including the public, legislators, and third-party payers, about the nature of opiate addiction, its anticipated outcomes, and the benefits of treatment. Methadone is commonly seen as a "chemical crutch," and opioid substitution therapy is viewed as replacing one drug with another. Added to such philosophical and ideological reservations may be fears of public and personal safety stemming from drug sales or clients' loitering in neighborhoods where opioid substitution therapy programs are located.

Treatment program staff must make efforts to overcome misconceptions concerning opioid addiction and inform the public about the entire range of treatment options and the overall positive benefits of opioid substitution therapy. They can do this through networking, public education (giving examples of patients who were helped by substitution therapy), and outreach.

Treatment program staff must make efforts to overcome misconceptions concerning opioid addiction and inform the public about the entire range of treatment options and the overall positive benefits of opioid substitution therapy.

## Organization of This TIP

This TIP provides guidelines for meeting patient needs in opioid substitution therapy. It takes into consideration the needs of patients, limited resources, the current knowledge base, and outcome evaluation.

Chapter 2 Assessing Patient Needs provides a brief overview of opioid substitution therapy and definitions of terms used in the TIP. Guidelines are offered for conducting both a preliminary assessment to determine a person's appropriateness for substitution therapy and a comprehensive biopsychosocial assessment upon entry into the program. Areas to assess are recommended, including the patient's expectations and motivation. Effective matching depends on careful ongoing assessment, which is also discussed.

Chapter 3 Phases of Treatment proposes a six-phase model of opioid substitution therapy that includes the acute and rehabilitation phases, the supportive care phase, medical maintenance, tapering and readjustment, and aftercare. Patient needs characteristic of each phase are described, and strategies for meeting these needs are outlined. Clinical indicators for transition into other treatment phases are described.

Chapter 4 Treatment Elements looks at core services essential for opioid substitution therapy programs and the responsibilities of staff from various disciplines who facilitate the use of treatment matching strategies in these programs. Common comorbid medical and psychiatric disorders are discussed and the roles of counseling and psychotherapy are summarized. Special considerations, such as childcare and access for disabled persons, are addressed.

Chapter 5 Self-Monitoring and Evaluation addresses the importance of program self-monitoring and evaluation of treatment outcomes. Goals of these processes are outlined, and a step-by-step guide for conducting self-monitoring and evaluation is presented. A detailed hypothetical example is included in an easy-to-follow chart format that lays out the evaluation steps described in the text.

Chapter 6 Cost-Effectiveness of Opioid Substitution Therapy addresses the costs of opioid substitution therapy services and describes approaches to calculating treatment costs.

Appendix A, lists references cited in the text, as well as other useful articles. Appendix B contains the Massachusetts Methadone Treatment Criteria, which were modeled on the American Society of Addiction Medicine patient placement criteria (American Society of Addiction Medicine, 1991). They provide admission, continuing care, and discharge criteria for AOD abuse treatment including methadone substitution therapy. For readers who are interested in designing and conducting research on the costs of AOD treatment, Appendix C presents several methodological approaches to consider. Appendix D is a list of the Federal resource panel members who contributed suggestions during the initial phases of the development of this TIP. Appendix E is a list of experts who participated in the field review of the TIP.