# Appendix E—Field Reviewers

- Cynthia E. Aiken, M.S.
- Executive Director
- Program Sponsor
- Narcotic Drug Treatment Center, Inc.
- Anchorage, Alaska
- Kenneth Teruya Akinaka, M.R.A.
- Quality Improvement Coordinator
- Bay Area Addiction Research and Treatment, Inc.
- San Francisco, California
- Daniel Alfieri
- Executive Director
- New Horizon Treatment Services, Inc.
- Trenton, New Jersey
- Charles A. Ausherman, M.S.W, C.S.A.C.
- Clinical Substance Abuse Counselor
- Pitt County Mental Health, Developmental Disabilities, and Substance Abuse Center
- Greenville, North Carolina
- G. Dean Austin, M.A.
- Chief, Licensure Section
- Division of Substance Abuse and Health Promotion
- Iowa Department of Public Health
- Des Moines, Iowa
- Doug Baker, M.S., C.S.A.C.
- Head, Adult Services Branch
- Substance Abuse Services Section
- Division of Mental Health/Developmental Disabilities/Substance Abuse Services
- Raleigh, North Carolina
- Cynthia Banfield-Weir, L.I.C.S.W., B.C.D.
- Clinical Director
- Center for Health and Human Services
- Wareham, Massachusetts
- Peter Banys, M.D.
- Department of Psychiatry
- Veterans Affairs Medical Center
- San Francisco, California
- Richard J. Bilangi, M.S.
- President
- Connecticut Counseling Center, Inc.
- Norwalk, Connecticut
- Kathy Blumenthal, M.S.
- Director, External Programs
- Great Brook Valley Health Center
- Worcester, Massachusetts
- Dennis Bobo
- State Methadone Authority
- Bureau of Substance Abuse Services
- Madison, Wisconsin
- Gary K. Borrell, M.D.
- Medical Director
- Orange Quarters, Inc.
- Oklahoma City, Oklahoma
- LaVerne Bostic, Ph.D.
- Vice President, Health Services Treatment Assistance
- Addiction Treatment Services, Inc.
- Central Diagnostic and Referral Services
- Detroit, Michigan
- Nancy Bradley, M.S., C.S.A.C.
- Clinic Supervisor
- LaFrontera-Hope Center
- Tucson, Arizona
- Robert K. Brooner, Ph.D.
- Director, Associate Professor
- Southeast Baltimore Treatment Center
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland
- Oscar Bukstein, M.P.H., M.D.
- Assistant Professor of Psychiatry
- Western Psychiatric Institute and Clinic
- University of Pittsburgh School of Medicine
- Pittsburgh, Pennsylvania
- Carol B. Butler, C.C.D.C.
- Director, Drug Dependency Program
- Sinai Hospital
- Baltimore, Maryland
- John T. Carroll, N.C.A.C. II
- Division Director, Substance Abuse Services
- Crozer-Chester Medical Center
- Chester, Pennsylvania
- Donna H. Caum, M.S.S.W.
- Treatment Program Consultant, Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, Tennessee
- Lois R. Chatham, Ph.D.
- Senior Research Scientist, Institute of Behavioral Research
- Texas Christian University
- Fort Worth, Texas
- Rick Christensen, P.A., C.A.S.
- Director Medical Services
- Valle Del Sol, Inc.
- Phoenix, Arizona
- Anthony C. Clemente, M.A., C.S.W.
- Executive Director
- Medical Resource Center, Inc.
- Michigan Counseling Services
- Madison Heights, Michigan
- Shirley Coletti
- President
- Operation PAR, Inc.
- St. Petersburg, Florida
- Ward S. Condelli, Ph.D.
- Research Sociologist, Center for Social Research and Policy Analysis
- Research Triangle Institute
- Research Triangle Park, North Carolina
- Mary L. Costa, R.N., A.A.S.
- Alcohol and Drug Program Inspector
- Department of Public Health and Addiction Services
- Hartford, Connecticut
- Thomas H. Coyne, C.S.W., C.A.S., C.S.A.C.
- Director, National Training Education and Consultation Services and Adjunct Professor
- Adelphi University
- Graduate School of Social Work
- Garden City Park, New York
- Anthony D. Crisp, M.A.
- Substance Abuse Services Director
- Substance Abuse Administration
- City of Norfolk Community Services Board
- Norfolk, Virginia
- Cynthia C. Crone, M.N.Sc., C.P.N.P.
- Director
- Arkansas Center for Addiction
- Research, Education, and Services
- Little Rock, Arkansas
- Helen Danser, R.Ph.
- Pharmacy Services Program Manager
- Division of Mental Health
- Department for Mental Health and Mental Retardation Services
- Frankfort, Kentucky
- Peter A. DeMaria, Jr., M.D.
- Medical Director, Narcotic Addict Rehabilitation Program
- Thomas Jefferson University
- Philadelphia, Pennsylvania
- David P. Donarski, M.D.
- Chair
- Wisconsin Controlled Substances Board
- Green Bay, Wisconsin
- John E. Emmel, M.D.
- Medical Director
- Department of Alcohol and Other Drug
- Abuse Services of Charleston County
- Charleston, South Carolina
- Barbara Brayton Espey, M.S.W., M.B.A.
- Deputy Director, Bureau of Substance Abuse Services
- Department of Public Health
- Commonwealth of Massachusetts
- Boston, Massachusetts
- Garland S. Ferguson
- Director, Division of Detoxification
- Bureau of Alcohol and Drug Abuse Prevention
- Arkansas Department of Health
- Benton, Arkansas
- Ruth Fishbein, M.A., M.S.W.
- Project Director, Quality Improvement Collaborative
- Health and Addictions Research, Inc.
- Boston, Massachusetts
- John Flint, M.D.
- Medical Director
- Operation PAR, Inc.
- St. Petersburg, Florida
- Patrick M. Flynn, Ph.D.
- Senior Research Psychologist
- Substance Abuse Treatment Research Program
- Research Triangle Institute
- Research Triangle Park, North Carolina
- Paul J. Fudala, Ph.D.
- Research Assistant Professor, Department of Psychology
- Veterans Affairs Medical Center
- Philadelphia, Pennsylvania
- Marcia Kraft Goin, M.D., Ph.D.
- Clinical Professor of Psychiatry
- University of Southern California
- School of Medicine
- Los Angeles, California
- Helen Patton Gray
- Administrator
- Valley Health Services
- Menasha, Wisconsin
- Randall B. Greene, D.O.
- Medical Director
- The Colonial Group, P.A.
- Orlando, Florida
- Larry K. Harcum, M.Ed.
- Substance Abuse Specialist
- Behavioral Pharmacology Research Unit
- Department of Psychiatry
- Johns Hopkins University School of Medicine
- Baltimore, Maryland
- Debra Henderson, M.S.W., A.C.S.W.
- Program Director, Midtown Mental Health
- Methadone Clinic
- Wishard Hospital
- Indianapolis, Indiana
- James Herrera, M.A.
- Senior Counselor, Center on Alcoholism, Substance Abuse, and Addictions
- University of New Mexico
- Albuquerque, New Mexico
- Edward J. Higgins, M.A.
- Executive Director
- Jersey Shore Addiction Services, Inc.
- Asbury Park, New Jersey
- Mark Hirschman, M.A.
- Director
- Montgomery County Methadone Center
- Norristown, Pennsylvania
- Jeffrey A. Hoffman, Ph.D.
- Executive Director, Center for Drug Treatment and Research
- Koba Institute
- Washington, D.C.
- Robert Holden, C.C.D.T.
- Director
- Partners In Drug Abuse, Rehabilitation, and Counseling
- Washington, D.C.
- Alfonso D. Holliday, II, M.D., M.B.A., A.S.A.M. (Certified)
- President/Medical Director, Methadone Maintenance and Detoxification Program
- Holliday Health Care, P.C.
- Gary, Indiana
- Iris C. Holliday, R.N., N.P., B.S.N., M.H.S., C.A.R.N.
- Clinic Supervisor, Methadone Maintenance and Detoxification Program
- Holliday Health Care, P.C.
- Gary, Indiana
- Elizabeth W. Imeson, M.D., M.P.H.
- Medical Director
- Southland Counseling Center
- Lansing, Michigan
- Loren A. Jones
- Director, Division of Alcoholism and Drug Abuse
- State of Alaska
- Juneau, Alaska
- Edith Jungblut
- Project Officer, Special Projects Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Carolann Kane-Cavaiola, M.A., C.C.D.S.
- Director, Addiction Services
- Center for Drug/Alcohol Prevention and Treatment
- JFK Medical Center
- Avenel, New Jersey
- Janice F. Kauffman, R.N., M.P.H., C.A.S.B Co-Chair
- Director, Substance Abuse Treatment Services
- North Charles, Inc.
- Harvard Medical School
- Department of Psychiatry
- Cambridge Hospital and Associate Director
- The Addictions Consultation and Education Team
- Division of Psychiatry
- Brigham and Women's Hospital
- Boston, Massachusetts
- Andrew J. V. Klein, M.D., F.A.C.P.
- Medical Director
- Honesty House
- Orange, New Jersey
- James R. Koger, M.S.W., M.S., C.S.A.C., C.A.S.
- Program Director Substance Abuse Treatment
- Long Island Jewish Medical Center
- New Hyde Park, New York
- Thomas R. Kosten, M.D.
- Director, Division of Substance Abuse
- Yale University
- New Haven, Connecticut
- Frances Rudnick Levin, M.D.
- Associate Director of Substance Abuse Education
- New York State Psychiatric Institute
- Columbia University
- New York, New York
- David Ley, Ph.D., L.C.S.W.
- Director, Psychosocial Services
- Erie Family Health Center
- Chicago, Illinois
- Sheera M. Lipshitz, M.H.S., C.A.A.C.
- Assertive Treatment Team Director
- Brandywine Counseling, Inc.
- Wilmington, Delaware
- James W. Luckey, Ph.D.
- Research Psychologist
- Substance Abuse Treatment Program and Center for Community-Based Treatment Research Methods
- Research Triangle Park, North Carolina
- James F. Maddux, M.D.
- Professor, Department of Psychiatry
- University of Texas Health Science
- Center at San Antonio
- San Antonio, Texas
- Stephen Magura, Ph.D., C.S.W.
- Director, Institute for Treatment and Services Research
- National Development and Research Institutes
- New York, New York
- Kay Malone, R.N., C.D., M.H.S.
- Nursing Supervisor/Projects Director
- Brandywine Counseling Inc.
- Wilmington, Delaware
- Margaret E. Mattson, Ph.D.
- Health Scientist Administrator, Treatment Research Branch
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland
- John J. McCarthy, M.D.
- Executive/Medical Director
- Bi-Valley Medical Clinic, Inc.
- Sacramento, California
- Linda S. McCorkle
- Treatment Consultant, Bureau of Alcohol and Drug Abuse Services
- State of Tennessee Department of Health
- Nashville, Tennessee
- Forrest B. Miller, M.D.
- Medical Director, Assistant Professor of Pharmacology and Toxicology
- Substance Abuse Treatment Clinic
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas
- Phillip S. Mosby, M.S.W., A.C.S.W.
- Executive Director
- Genesee County Commission on Substance Abuse Services
- Flint, Michigan
- Edward V. Nunes, M.D.
- Research Psychiatrist and Assistant
- Professor of Clinical Psychiatry
- New York State Psychiatric Institute
- New York, New York
- Philip O'Dwyer, Ed.D., C.S.W., C.A.C.
- Clinical Director
- Brookfield Clinics, Inc.
- Garden City, Michigan
- Roger Peele, M.D.
- Chair, Department of Psychiatry
- Commission on Mental Health Services
- St. Elizabeth's Campus
- Washington, D.C.
- Bruce Phariss, M.D.
- Psychiatrist
- The New York Hospital/Payne Whitney Clinic
- New York, New York
- Margaret L. Polinsky, M.S.W., Ph.D.
- Assistant Research Social Worker, Drug Abuse Research Center
- Neuropsychiatric Institute
- University of California, Los Angeles
- Los Angeles, California
- Michael L. Prendergast, Ph.D.
- Project Director
- UCLA Drug Abuse Research Center
- Los Angeles, California
- Richard A. Rawson, Ph.D.
- Executive Director
- Matrix Center
- Beverly Hills, California
- Phyllis G. Reilly, M.A., C.A.D.C.
- Director, Addiction Recovery Services
- University of Medicine and Dentistry of
- New Jersey Community Mental Health Center at Piscataway
- Piscataway, New Jersey
- John A. Renner, Jr., M.D., C.A.S.
- Associate Professor of Psychiatry, Boston University School of Medicine
- Psychiatry Service
- Veterans Affairs Outpatient Clinic
- Boston, Massachusetts
- Philip F. Richmond, M.S., C.A.D.C.
- Associate Director
- The Hartford Dispensary
- Hartford, Connecticut
- Michael Rizzi
- Deputy Director
- CODAC Treatment Centers
- Cranston, Rhode Island
- Richard S. Schottenfeld, M.D.
- Associate Professor of Psychiatry, and Director, Substance Abuse Treatment Center
- Yale University School of Medicine
- New Haven, Connecticut
- D. Dwayne Simpson, Ph.D.
- Director and Professor, Institute of Behavioral Research
- Texas Christian University
- Fort Worth, Texas
- Janice D. Sneed, M.H.S., N.C.A.C. II
- Clinical Director
- Brandywine Counseling Inc.
- Wilmington, Delaware
- Noreen Sobol, A.R.R.T.
- Medical/Clinical Administrative Liaison
- NPL Inc.
- Highland Park, Michigan
- Keith E. Spare, M.S., M.Div., L.P.C., C.S.A.C. II
- Program Manager
- Rodgers South
- Kansas City, Missouri
- Donald Storms, C.A.C., C.D.A.C., C.H.I.V.C., C.S.A.T.-T.O.T.
- Director, Early Intervention Program
- New York City Department of Health
- Hamden, Connecticut
- Kenneth Sunamoto, M.D.
- Medical Director
- Drug Addiction Services of Hawaii, Inc.
- Honolulu, Hawaii
- Steve V. Tapscott, M.A., L.C.D.C.
- Chairman
- Texas Methadone Treatment Association, Inc.
- Houston, Texas
- James L. Tomarken, M.D., M.S.W.
- Assistant Director, Clinical Affairs
- Addiction Research Foundation
- Toronto, Ontario
- Canada
- James N. Wardell, M.D.
- Medical Director
- Eleanor Hutzel Recovery Center
- Detroit, Michigan
- Richard Weisskopf
- Manager, Methadone Treatment Services
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois
- Mark L. Willenbring, M.D.
- Associate Professor of Psychiatry
- University of Minnesota School of Medicine
- Veterans Affairs Medical Center
- Minneapolis, Minnesota
- John Willson, M.S.W.
- Michigan State Methadone Authority
- Center for Substance Abuse Services
- Michigan Department of Public Health
- Lansing, Michigan
- Mark G. Winiarski, Ph.D.
- Project Director, AIDS Mental Health and Primary Care Integration Project
- Montefiore Medical Center
- Bronx, New York
- Dennis R. Wong, A.C.S.W.
- Program Development Specialist, Alcohol and Drug Program Office
- Multnomah County, Oregon
- Portland, Oregon
- George E. Woody, M.D. B Co-Chair
- Chief, Substance Abuse Treatment Unit
- Veterans Affairs Medical Center and Clinical Professor, Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania