# Appendix D—Federal Resource Panel

- Brad Austin, M.P.H.
- Public Health Advisor, Treatment Operations and Review Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Mike Bacon, M.S.
- Public Health Advisor, HIV Linkage Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- James Callahan, D.P.A.
- American Society of Addiction Medicine
- Chevy Chase, Maryland
- Sandra M. Clunies, M.S., N.C.A.D.C.
- Government Project Officer, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Herman I. Diesenhaus, Ph.D.
- Review Administrator
- Office of Extramural Activities Review
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Margaret Easter, R.N., M.N., Retired
- Public Health Advisor, HIV Linkage Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Bennett W. Fletcher, Ph.D.
- Research Psychologist, Services Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland
- George R. Gilbert
- Director, Office of Policy Coordination
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- John Gregrich
- Senior Policy Analyst, Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.
- David L. Griffith, M.Ed., M.S., R.N.
- Public Health Advisor, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Harry W. Haverkos, M.D.
- Director, Office on AIDS
- National Institute on Drug Abuse
- Rockville, Maryland
- Barbara H. Herman, Ph.D.
- Director, Opioid Medication Trials
- Clinical Trials Branch
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, Maryland
- Ruth H. Carlsen Kahn, R.N., D.N.Sc.
- Health Professions Education Specialist, Division of Medicine
- Bureau of Health Professions
- Health Resources and Services Administration
- Rockville, Maryland
- Janice Fay Kauffman, R.N., M.P.H., C.A.S. -- Co-Chair
- Director, Substance Abuse Treatment Services
- North Charles, Inc.
- Harvard Medical School
- Department of Psychiatry
- Cambridge Hospital and Associate Director, Addictions Consultation and Education Team
- Division of Psychiatry
- Brigham and Women's Hospital
- Boston, Massachusetts
- Robert Lubran, M.P.A.
- Chief, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Margaret E. Mattson, Ph.D.
- Health Scientist Administrator, Treatment Research Branch
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland
- Richard Rettig, Ph.D.
- Study Director, Federal Regulation of Methadone Treatment
- Institute of Medicine
- Washington, D.C.
- Charles Roberts, Ph.D.
- Mathematical Statistician, Information Systems and Analysis Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- George E. Woody, M.D. -- Co-Chair
- Chief, Substance Abuse Treatment Unit
- Veterans Affairs Medical Center and Clinical Professor, Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania