# Appendix A -- Bibliography

[no authors]. Acupuncture: the position paper of the National Council Against Fraud. American Journal of Acupuncture. 1991;;19(3):273-279.
Adinoff, B. Long-term therapy with benzodiazepines despite alcohol dependence disorder: seven cases reported. American Journal on Addictions. 1992;;1(4): 288-293.
Allison, M., Hubbard, R.L. Drug abuse treatment process: a review of the literature. International Journal of the Addictions. 1985;;20(9):1321-1345. [pmid: 3000959].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC: American Psychiatric Association. 1994.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders. Washington, DC: American Society of Addiction Medicine. 1991.
Anglin, M.D., Hser, Y.I. Treatment of drug abuse. In: Tonry, M., and Wilson, J.Q., eds. Drugs and Crime. Chicago, IL: University of Chicago Press; 1990: 393-460.
Anglin, M.D., McGlothlin, W.H. Outcome of narcotic addict treatment in California. In: Tims, F.M., Ludford, J. P. Drug Abuse Treatment Evaluation: Strategies, Progress and Prospects. Rockville, MD: National Institute of Drug Abuse; 1984: 106-128. US Department of Health and Human Services publication ADM 88-1329. NIDA Research Monograph 51.
Anglin, M.D., Powers, K.I. Methadone treatment and legal supervision: individual and joint effects on the behavior of narcotics addicts. Journal of Applied Behavioral Science. 1991;;27(4):515-531.
Apsler, R., Harding, W.M. Cost-effectiveness analysis of drug abuse treatment: Current status and recommendations for future research. In: Background Papers on Drug Abuse Financing and Services Research. Rockville, MD: National Institute of Drug Abuse Services Research Series; 1991: 58-81. US Department of Health and Human Services publication ADM 91-1777.
Arndt, I.O., Dorozynsky, L., McLellan, A.T., Woody, G.E., O'Brien, C.P. Desipramine treatment of cocaine dependence in methadone-maintained patients. Archives of General Psychiatry. 1992;;49(11):888-893. [pmid: 1444727].
Babst, D.V., Chambers, C.D., Warner, A. Patient characteristics associated with retention in a methadone maintenance program. British Journal of the Addictions of Alcohol and Other Drugs. 1971;;66(3):195-204.
Ball, J.C., Ross, A. The Effectiveness of Methadone Maintenance Treatment: Patients, Programs, Services, and Outcome. New York, NY: Springer-Verlag; 1991.
Beck, A.T., Wright, F.D., Newman, C.F., Liese, B.S. Cognitive Therapy of Substance Abuse. New York, NY: Guilford Press. 1993.
Beschner, G., Walters, J.M. Just another habit? The heroin user's perspective on treatment. In: Hanson, B., Beschner, G., Walters, J.M., Bovelle, E., eds. Life With Heroin: Voices from the Inner City. Lexington, MA: Lexington Books; 1985: 155-173.
Boudin, H. Contingency contracting as a therapeutic tool in the deceleration of amphetamine use. Behavioral Therapy. 1972;;3(4):604-608.
Brahen, L.S., Capone, T., Bloom, S. An alternative to methadone for probationer addicts: narcotic antagonist treatment. Contemporary Drug Issues. 1978;;13:117-132.
Caplehorn, J.R., Bell, J. Methadone dosage and retention of patients in maintenance treatment. Medical Journal of Australia. 1991;;154(3):195-199. [pmid: 1988793].
Chaisson, R.E., Bacchetti, P., Osmond, D., et al. Cocaine use and HIV infection in intravenous drug users in San Francisco. Journal of the American Medical Association. 1989;;261(4):561-565. [pmid: 2909798].
Chambers, C.D., Taylor, W.J., Moffett, A.D. The incidence of cocaine abuse among methadone maintenance patients. International Journal of the Addictions. 1972;;7(3):427-441. [pmid: 5085276].
Condelli, W.S. Strategies for increasing retention in methadone programs. Journal of Psychoactive Drugs. 1993;;25(2):143-147. [pmid: 8377082].
Condelli, W.S., Fairbank, J.A., Dennis, M.L., Rachal, J.V. Cocaine use by clients in methadone programs: significance, scope, and behavioral interventions. Journal of Substance Abuse Treatment. 1991;;8(4): 203-212.
Cornish, J.W., Henson, D., Levine, S., et al. Naltrexone maintenance: effects of morphine sensitivity in normal volunteers. American Journal on Addictions. 1993;;2:34-38.
D'Aunno, T., Vaughn, T.E. Variations in methadone treatment practices: results from a national study. Journal of the American Medical Association. 1992;;267(2):253-258. [pmid: 1727522].
Dodes, L.M., Khantzian, E.J. Psychotherapy and chemical dependence. In: Ciraulo, D.A., Shader, R.I., eds. Clinical Manual of Chemical Dependence. Washington, DC: American Psychiatric Press; 1991.
Dole, V.P., Joseph, H. Long-term outcome of patients treated with methadone maintenance. Annals of the New York Academy of Sciences. 1978;;311:181-189.
Dole, V.P., Nyswander, M.E., Kreek, M.J. Narcotic blockade. Archives of Internal Medicine. 1966;;118(4): 304-309.
Dusenbury, L., Khuri, E., Millman, R.B. Adolescent substance abuse: a sociodevelopmental perspective. In: Lowinson, J., Ruiz, P., Millman, R.B., Langrod, J., Substance Abuse: A Comprehensive Textbook. 2nd ed. Baltimore, MD: Williams & Wilkins; 1992: 832-851.
Egan, G. The Skilled Helper: A Model for Systematic Helping and Interpersonal Relating. Monterey, CA: Brooks/Cole. 1975.
Fairbank, J.A., Bonito, A.J., Dennis, M.L., Rachal, J.V. Enhanced Counselor's Manual. Research Triangle Park, NC: Research Triangle Institute. 1991.
Fairbank, J.A., Dunteman, G.H., Condelli, W.S. Do methadone patients substitute other drugs for heroin? Predicting substance abuse at 1-year follow-up. American Journal of Drug and Alcohol Abuse. 1993;;19(4):465-474. [pmid: 8273767].
Finnegan, L.P. Treatment issues for opioid-dependent women during the perinatal period. Journal of Psychoactive Drugs. 1991;;23(2):191-201. [pmid: 1765892].
French, M.T. Economic evaluation of drug abuse treatment programs: methodology and findings. American Journal of Drug and Alcohol Abuse. 1995; in press.
Gearing, F.R., Schweitzer, M.D. An epidemiologic evaluation of long-term methadone maintenance for heroin addiction. American Journal of Epidemiology. 1974;;100(2):101-112. [pmid: 4850534].
Gerstein, D.R., Harwood, H.J. The effectiveness of treatment. In: Institute of Medicine, Treating Drug Problems. Washington, DC: National Academy Press; 1990; 1:132-199.
Glosser, D.S. The use of a token economy to reduce illicit drug use among methadone maintenance clients. Addictive Behaviors. 1983;;8(2):93-104. [pmid: 6613720].
Graham, N.M., Nelson, K.E., Soloman, L., et al. Prevalence of tuberculin positivity and skin test anergy in HIV-1 seropositive and -seronegative intravenous drug users. Journal of the American Medical Association. 1992;;267(3):369-373. [pmid: 1727959].
Hargreaves, W.A. Methadone dose and duration for maintenance treatment. In: Cooper, J.R., Allman, F., Brown, B.S., Czechowicz, D., eds. Research on the Treatment of Narcotic Addiction: State of the Art. Washington, DC: US Government Printing Office; 1983.
Hartel, D., Selwyn, P.A., Schoenbaum, E.E., et al. Methadone maintenance treatment and reduced risk of AIDS and AIDS-specific mortality in intravenous drug users. Abstract No. 8546. Proceedings of the Fourth International Conference on AIDS. Stockholm; 1988.
Hartgers, C., Coutinho, R.A., Krijnen, P.A., van den Hoek, R. HIV prevalence and risk behavior among injecting drug users who participate in "low-threshold" methadone programs in Amsterdam. American Journal of Public Health. 1992;;82(4):547-551. [pmid: 1312311].
Harwood, H.J., Napolitano, D.M, Kristiansen, P. L., Collins, J.J. Economic Costs to Society of Alcohol and Drug Abuse and Mental Illness: 1980. Contract RTI/2734/00-01FR. Research Triangle Park, NC: Research Triangle Institute; 1984.
Hoffman, J.A., Moolchan, E.T. The phases-of-treatment model for methadone maintenance: implementation and evaluation. Journal of Psychoactive Drugs. 1994;;26(2):181-197. [pmid: 7931863].
Horn, D., Waingrow, S. Some dimensions of a model for smoking behavior change. American Journal of Public Health and the Nations Health. 1966;;56(12):21-26.
Hubbard, R.L., Marsden, M.E. Relapse to use of heroin, cocaine, and other drugs in the first year after treatment. In: Tims, F.M., Leukefeld, C.G., eds. Relapse and Recovery in Drug Abuse. Rockville, MD: National Institute on Drug Abuse; 1986; 157-166. US Department of Health and Human Services publication ADM 88-1473. NIDA Research Monograph 72.
Hubbard, R.L., Marsden, M.E., Rachal, J.V., Harwood, H.J., Cavanaugh, R.R., Ginzburg, H.M. Drug Abuse Treatment: a National Study of Effectiveness. Chapel Hill, NC: University of North Carolina Press; 1989.
Hunt, D.E., Lipton, D.S., Goldstein, D.S., Strug, D.L., Spunt, B. It takes your heart: the image of methadone maintenance in the addict world and its effect on recruitment into treatment. International Journal of the Addictions. 1985;;20(11-12):1751-1771.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, DC: National Academy Press; 1990a.
Institute of Medicine. Federal Regulation of Methadone Treatment. Washington, DC: National Academy Press; 1995.
Institute of Medicine. Treating Drug Problems, Volume 1: A Study of the Evolution, Effectiveness and Financing of Public and Private Drug Treatment Systems. Washington, DC: National Academy Press; 1990b.
Joe, G.W., Simpson, D.D., Hubbard, R.L. Treatment predictors of tenure in methadone maintenance. Journal of Substance Abuse. 1991;;3(1):73-84. [pmid: 1821275].
Johnson, L.D., O'Malley, P.M., Backman, J.G. Highlights from Drugs and American High School Students: 1975-1977. Rockville, MD: National Institute on Drug Abuse; 1984. US Department of Health and Human Services publication ADM 84-1317.
Joseph, H. Substance abuse and homeless within the inner cities. In: Lowinson, J.H., Ruiz, P., Millman, R.B., Langrod, J.G. Substance Abuse: A Comprehensive Textbook. 2nd ed. Baltimore, MD: Williams & Wilkins; 1992: 875-889.
Keeler, E.B., Wells, K.B., Manning, W.G., Rumpel, J.D., Hanley, J.M. The Demand for Episodes of Mental Health Services. Rockville, MD: National Institutes of Mental Health; 1986. Contract R-3432.
Khantzian, E.J., Halliday, K.S., McAuliffe, W. E. Addiction and the Vulnerable Self: Modified Dynamic Group Therapy for Substance Abusers. New York, NY: Guilford Press; 1990.
Kleber, H.D. Opioid detoxification. In: Galanter, M., Kleber, H.D., eds. Textbook of Substance Abuse Treatment. Washington, DC: American Psychiatric Press; 1994: 204-205.
Kleber, H.D., Topazian, M., Gaspari, J., Riordan, C.E., Kosten, T. Clonidine and naltrexone in the outpatient treatment of heroin withdrawal. American Journal of Drug and Alcohol Abuse. 1987;;13(1-2):1-17.
Kosten, T.R. Client issues in drug abuse treatment: addressing multiple drug abuse. In: Pickens, R.W., Leukefeld, C.G., Schuster, C.R., eds. Improving Drug Abuse Treatment. Rockville, MD: National Institute on Drug Abuse; 1991: 136-151. US Department of Health and Human Services publication ADM 91-1754. NIDA Research Monograph 106.
Kosten, T.R., Morgan, C.M., Falcione, J., Schottenfeld, R.S. Pharmacotherapy for cocaine-abusing methadone-maintained patients using amantadine or desipramine. Archives of General Psychiatry. 1992;;49(11):894-898. [pmid: 1444728].
Kreek, M.J. Medical complications in methadone patients. Annals of the New York Academy of Sciences. 1978;;311:110-134.
Kreek, M.J. Using methadone effectively: achieving goals by application of laboratory, clinical, and evaluation research and by development of innovative programs. In: Pickens, R.W., Leukefeld, C.G., Schuster, C.R., eds. Improving Drug Abuse Treatment. Rockville, MD: National Institute on Drug Abuse; 1991: 245-266. US Department of Health and Human Services publication ADM 91-1754. NIDA Research Monograph 106.
Kreek, M.J., Dodes, L., Kane, S., Knobler, J., Martin, R. Long-term methadone maintenance therapy: effects on liver function. Annals of Internal Medicine. 1972;;77(4):598-602. [pmid: 4629927].
Ling, W., Charuvastra, C., Kaim, S.C., Klett, C.J. Methadyl acetate and methadone as maintenance treatments for heroin addicts: a Veterans Administration cooperative study. Archives of General Psychiatry. 1976;33(6):709-720. [pmid: 779705].
Loimer, N., Schmid, R., Grunberger, J., et al. Psychophysiological reactions in methadone maintenance patients do not correlate with methadone plasma levels. Psychopharmacology. 1991;;103(4):538-540. [pmid: 2062987].
Luborsky, L., Woody, G.E., Hole, A.V., Velleco, A. Special manual for dynamic therapy of drug dependence: adaptation of the general manual for supportive-expressive psychotherapy. In: Barber J., Crits-Christoph, P., eds. Psychodynamic Psychotherapies for Axis I Disorders. New York, NY: Basic Books; 1994.
Maddux, J.F., Prihoda, T.J., Desmond, D.P. Treatment fees and retention on methadone maintenance. Journal of Drug Issues. 1994;;24(3):429-443.
Magura, S., Siddiqi, Q., Freemen, R., Lipton, D.S. Changes in cocaine use after entry into methadone treatment. Unpublished. New York, NY: Narcotic and Drug Research, Inc.; 1991.
Marsh, K.L., Joe, G.W., Simpson, D.D., Lehman, W.E. Treatment history. In: Simpson, D.D., Sells, S.B., eds. Opioid Addiction and Treatment: A 12-Year Follow-Up. Malabar, FL: Robert E. Krieger Publishing Company; 1990: 137-156.
Massachusetts Department of Public Health, Division of Substance Abuse Services. Massachusetts Criteria: Admission, Continuing Care, and Discharge. Boston, MA: Bureau of Substance Abuse Services; 1992.
McGlothlin, W.H., Anglin, M.D. Long-term follow-up of clients of high- and low-dose methadone programs. Archives of General Psychiatry. 1981a;;38(9):1055-1063. [pmid: 7283663].
McLellan, A.T., Alterman, A.I. Patient treatment matching: a conceptual and methodological review with suggestions for future research. In: Pickens, R.W., Leukefeld, C.G., Schuster, C.R., eds. Improving Drug Abuse Treatment. Rockville, MD: National Institute on Drug Abuse; 1991: 114-135. US Department of Health and Human Services. publication ADM 91-1754. NIDA Research Monograph 106.
McLellan, A.T., Alterman, A.I., Cacciola, J., Metzger, D.S., O'Brien, C.P. A new measure of substance abuse treatment: initial studies of the treatment services review. Journal of Nervous and Mental Disease. 1992;180(2):101-110. [pmid: 1737971].
McLellan, A.T., Luborsky, L., O'Brien, C.P., Woody, G.E. An improved diagnostic evaluation instrument for substance abuse patients: The Addiction Severity Index. Journal of Nervous and Mental Disease. 1980;;168(1):26-33. [pmid: 7351540].
McLellan, A.T., Luborsky, L., Woody, G.E., O'Brien, C.P., Druley, K.A. Increased effectiveness of substance abuse treatment: a prospective study of patient-treatment matching. Journal of Nervous and Mental Disorders. 1983b;;171(10): 597-605.
McLellan, A.T., Woody, G.E., Luborsky, L., Goehl, L. Is the counselor an "active ingredient" in substance abuse rehabilitation? An examination of treatment success among four counselors. Journal of Nervous and Mental Disease. 1988;;176(7):423-430. [pmid: 3411312].
Metzger, D.S., Woody, G.E., McLellan, A.T., et al. HIV seroconversion among intravenous drug users in and out-of-treatment. Journal of Acquired Immune Deficiency Syndrome. 1993;;6(9):1049-1056.
Milby, J.B., Gurwitch, R.H., Hohmann, A.A., et al. Assessing pathological detoxification fear among methadone patients: the DFSS. Journal of Clinical Psychology. 1987;;43(5):528-538. [pmid: 3667947].
Miller, W.R., Rollnick, S. Motivational Interviewing: Preparing People to Change Addictive Behavior. New York, NY: Guilford Press; 1991.
Millman, R.B., Khuri, E.T., Nyswander, M.E. Therapeutic detoxification of adolescent heroin addicts. Annals of the New York Academy of Sciences. 1978;;311:153-164.
National Institute on Drug Abuse. Background Papers on Drug Abuse Financing and Services Research. Drug Abuse Services Research Series. DHHS publication ADM 91-1777. Rockville, MD: National Institute on Drug Abuse; 1991.
National Institute on Drug Abuse. How Good Is Your Drug Abuse Treatment Program?. DHHS publication ADM 93-3608. Rockville, MD: National Institute on Drug Abuse; 1993.
National Institute on Drug Abuse. National Drug and Alcoholism Treatment Unit Survey (NDATUS): 1991 Main Findings Report. Rockville, MD; 1993. Department of Health and Human Services SMA 93-2007.
National Institute on Drug Abuse. Relapse Prevention: More Support for Your Clients. DHHS publication ADM 93-3688. Rockville, MD: National Institute on Drug Abuse; 1993.
Novick, D.M., Joseph, H., Croxson, T.S., et al. Absence of antibody to human immunodeficiency virus in long-term, socially rehabilitated methadone maintenance patients. Archives of Internal Medicine. 1990;150(1):97-99. [pmid: 2297301].
Novick, D.M., Kreek, M.J., Fanizza, A.M., et al. Methadone disposition in patients with chronic liver disease. Clinical and Pharmacological Therapy. 1981;;30(3):353-362.
Nurco, D.N., Stephenson, P.E., Hanlon, T.E. Aftercare/relapse prevention and the self-help movement. International Journal of the Addictions. 1991;;25(9A-10A):1179-1200.
Parrino, M.W., ed. State Methadone Maintenance Treatment Guidelines. Rockville, MD: Center for Substance Abuse Treatment, US Department of Health and Human Services; 1993.
Payte, J.T. The use of insulin in the treatment of diabetes: an analogy to methadone maintenance. Journal of Psychoactive Drugs. 1991;;23(2):109-110. [pmid: 1765884].
Platt, Jerome J. Heroin Addiction: Theory, Research, and Treatment. Malabar, FL: Robert E. Krieger Publishing Company; 1986.
Presslich, O., Loimer, N., Lenz, K., Schmid, R. Opiate detoxification under general anesthesia by large doses of naloxone. Clinical Toxicology. 1989;;27(4-5):263-270.
Prochaska, J.O., DiClemente, C.C. Transtheoretical therapy: toward a more integrative model of change. Psychotherapy: Theory, Research and Practice. 1982;;19(3):276-288.
Rawson, R.A., Obert, J.L., McCann, M.J., Smith., D.P., Scheffey, E.H. The Neurobehavioral Treatment Manual: A Therapist Manual for Outpatient Cocaine Addiction Treatment. Beverly Hills, CA: Matrix Center; 1989.
Research Triangle Institute. Drug Abuse Treatment Cost Analysis Program (DATCAP): Cost Interview Guide for Provider Sites. A Training and Employment Program (TEP). Research Triangle Park, NC: Research Triangle Institute; 1993.
Resnick, R.B., Kestenbaum, R.S., Washton, A., Poole, D. Naloxone-precipitated withdrawal: a method for rapid induction onto naltrexone. Clinical Pharmacology and Therapeutics. 1976 1977;;21(4):409-413. [pmid: 849672].
Rounsaville, B.J., Tims, F.M., Harden, A.M., Solder, B.J., eds. Diagnostic Source Book on Drug Abuse Research and Treatment. Rockville, MD: National Institute on Drug Abuse; 1993. US Department of Health and Human Services publication ADM 93-3508.
Rounsaville, B.J., Weissman, M.M., Crits-Christoph, K., Wilver, C., Kleber, H. Diagnosis and symptoms of depression in opiate addicts: course and relationship to treatment outcome. Archives of General Psychiatry. 1982a;;39(2): 151-156.
Ruiz, P., Langrod, J. Substance abuse among Hispanic-Americans: current issues and future perspectives. In: Lowinson, J., Ruiz, P., Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins; 1992.
Ruiz, P., Langrod, J, Westermeyer, J. Cultural perspectives: Native Americans, Asians, and new immigrants. In: Lowinson, J., Ruiz, P., Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins; 1992.
Sandberg, G.G., Marlatt, G.A. Relapse prevention. In: Ciraulo, D.A., Shader, R.I., eds. Clinical Manual of Chemical Dependence. Washington, DC: American Psychiatric Press; 1991.
Saunders, B., Wilkinson, C., Allsop, S. Motivational intervention with heroin users attending a methadone clinic. In: Miller, W.R., Rollnick, S., eds. Motivational Interviewing. New York, NY: Guilford Press; 1991.
Schoenbaum, E.E., Hartel, D., Selwyn, P.A., et al. Risk factors for human immunodeficiency virus infection in intravenous drug users. New England Journal of Medicine. 1989;;321(13):874-879. [pmid: 2770823].
Schottenfield, R.S., Pascale, R., Sokolowski, S. Matching services to needs: vocational services for substance abusers. Journal of Substance Abuse Treatment. 1992;;9(1):3-8. [pmid: 1593662].
Simpson, D.D. DATAR Forms Manual: Drug Abuse Treatment for AIDS-Risk Reduction. Fort Worth, TX: Texas Christian University. 1992.
Simpson, D.D., Dansereau, D.F., Joe, G.W. The DATAR Project: cognitive and behavioral enhancements to community-based treatment. In: Tims, F.M., Fletcher, B.W., Inciardi, J.A., Delaney, P., Harden, A. M., eds. The Effectiveness of Innovative Strategies in the Treatment of Drug Abuse. Westport, CT: Greenwood Press. 1995.
Simpson, D.D., Joe, G.W. Motivation as a predictor of early dropout from drug abuse treatment. Psychotherapy. 1993;;30(2):357-368.
Simpson, D.D., Marsh, K.L. Relapse and recovery among opioid addicts 12 years after treatment. In: Tims, F.M., Leukefeld, C.G., eds. Relapse and Recovery in Drug Abuse. Rockville, MD: National Institute on Drug Abuse; 1986: 86-103. US Department of Health and Human Services publication 88-1473. NIDA Research Monograph 72.
Simpson, D.D., Savage, L.J. Treatment re-entry and outcomes of opioid addicts during a four-year follow-up after drug abuse treatment in the United States. Bulletin on Narcotics. 1980;32(4):1-10. [pmid: 6912076].
Simpson, D.D., Sells, S.B., eds. Opioid addiction and treatment: a 12-year follow-up. Malabar, Florida: Robert E. Krieger Publishing Company. 1990.
Simpson, D.D., Sells, S.B. Effectiveness of treatment for drug abuse: an overview of the DARP research program. Advances in Alcohol and Substance Abuse. 1982;2(1):7-29.
Stitzer, M.L., Iguchi, M.Y., Felch, L.J. Contingent take-home incentive: effects on drug use of methadone maintenance patients. Journal of Consulting and Clinical Psychology. 1992;60(6):927-934. [pmid: 1460154].
Tims, F.M., Fletcher, B.W., Inciardi, J.A., Delaney, P., Harden, A.M., eds. The Effectiveness of Innovative Strategies in the Treatment of Drug Abuse. Westport, CT: Greenwood Press. 1995; in press.
Tims, F.M., Ludford, J.P. Drug Abuse Treatment Evaluation: Strategies, Progress and Prospects. Rockville, MD: National Institute on Drug Abuse; 1984. US Department of Health and Human Services publication ADM 88-1329. NIDA Research Monograph 51.
Umbricht-Schneiter, A., Ginn, D.H., Pabst, K.M., Bigelow, G.E. Providing medical care to methadone clinic patients: referral vs. on-site care. American Journal of Public Health. 1994;84(2):207-210. [pmid: 8296941].
Weddington, W.W. Towards a rehabilitation of methadone maintenance: integration of relapse prevention and aftercare. International Journal of the Addictions. 1991;25(9A-10A):1201-1224.
Wheeler, J.R., Fadel, H., D'Aunno, T.A. Ownership and performance of outpatient substance abuse treatment centers. American Journal of Public Health. 1992;82(5):711-718. [pmid: 1314520].
Wolff, K., Sanderson, M., Hay, A.W., Raistrick, D. Methadone concentrations in plasma and their relationship to drug dosage. Clinical Chemistry. 1991;37(2):205-209. [pmid: 1993325].
Woody, G.E., Luborsky, L., McLellan, A.T., O'Brien, C.P., Beck, A.T., Blaine, J., et al. Psychotherapy for opiate addicts: does it help?. Archives of General Psychiatry. 1983;40(6):639-645. [pmid: 6847332].
Woody, G.E., McLellan, A.T., Luborsky, L., O'Brien, C.P. Psychotherapy in community methadone programs: a later validation study. American Journal of Psychiatry. 1995; in press.
Woody, G.E., O'Hare, K., Mintz, J., O'Brien, C. P. Rapid intake: a method for increasing retention rate of heroin addicts seeking methadone treatment. Comprehensive Psychiatry. 1975;16(2): 165-169.
Wright, J.D. The health of the homeless: evidence from the National Health Care for the Homeless Program. In: Brickner, P. et al., eds. Under the Safety Net: The Health and Social Welfare of the Homeless in the United States. New York, NY: W.W. Norton. 1990:15-31.
Yancovitz, S.R., Des Jarlais, D.C., Peyser, N., et al. A randomized trial of an interim methadone maintenance clinic. American Journal of Public Health. 1991;81(9):1185-1191. [pmid: 1659236].
Zinberg, N.E., Harding, W.M., eds. Control Over Intoxicant Use: Pharmacological, Psychological, and Social Considerations. New York, NY: Human Sciences Press. 1982.

### Other Authorities

Drugs Used for Treatment of Narcotic Addicts, 21 C.F.R. Part 291 Section 291. 501 (Methadone and the Maintenance Treatment of Narcotic Addicts), Section 291.505 (Conditions for the Use of Narcotic Drugs; Appropriate Methods of Professional Practice for Medical Treatment of the Narcotic Addictions of Various Classes of Narcotic Addicts Under Section 4 of the Comprehensive Drug Abuse Protection and Control Act of 1970) (1993).