# Foreword

One of the best opportunities we have to approach and intervene with the substance-using woman is when she is pregnant. The child's birth may give her a powerful motive to seek treatment for her addiction. Early intervention efforts during the prenatal period increase the likelihood that she will successfully recover from alcohol and other drug abuse.

It is equally important to provide the pregnant, substance-using woman with optimal, comprehensive obstetrical care. The results of prenatal drug exposure are well documented and can include intrauterine growth retardation, prematurity and low birth weight, central nervous system damage, and congenital physical malformations, among others.

A continuum of followup services is a third critical element for an improved quality of life for the substance-using woman and her family. She often lives in a stressful environment that may include physical and sexual abuse, single parenthood, and limited financial and social support. Interventions during the postnatal period are needed to help her successfully parent her child, abstain from the use of alcohol and other drugs, and address complex social needs.

The Center for Substance Abusement Treatment (CSAT) is keenly aware that pregnant, substance-using women and their children suffer from the adverse effects of addiction and is dedicated to enhancing and mobilizing the health and human services that they need. With this commitment, CSAT sought the advice and direction of a Federal Resource Panel. Based on their guidance, a national Consensus Panel of experts was convened. The medical care, alcohol and other drug treatment, and legal and ethical guidelines presented in this document are the result of their efforts.

On behalf of the Substance Abuse and Mental Health Services Administration and CSAT, we wish to express our grateful appreciation to the Consensus Panel Chair, Dr. Janet Mitchell, and to the many dedicated individuals who participated in the development of this Treatment Improvement Protocol.

These guidelines are intended to stimulate a wide variety of service providers to participate in crafting a full continuum of family-oriented services for pregnant, substance-using women and their children. The guidance offered by these protocols is the result of research knowledge and the clinical experience, careful deliberation, and heartfelt concern of Panel members. We invite you to use and adapt these models of care to strengthen your delivery of services to this at-risk population.

- Nelba Chavez, Ph.D.
- Administrator
- Substance Abuse and Mental Health Services Administration
- David J. Mactas
- Director
- Center for Substance Abuse Treatment