# Consensus Panel on Pregnant, Substance-Using Women

- Hortensia Amaro, Ph.D.
- Associate Professor
- Boston University School of Public Health in the School of Medicine
- Boston, Massachusetts

- Shirley Coletti
- President
- Operation PAR, Inc.
- A Comprehensive Drug Treatment, Prevention, Research, Training Program
- St. Petersburg, Florida

- Nancy Neueloff Dubler, LL.B.
- Director
- Division of Law and Ethics
- Montefiore Medical Center
- Bronx, New York

- Patricia E. Evans, M.D., M.P.H.
- Clinical Director
- Training, Evaluation, and Research of Substance Abuse Services
- Bayview-Hunter's Point Foundation
- San Francisco, California

- Teresa Hagan, M.S.W.
- Program Director
- Jefferson Family Center
- Department of Pediatrics
- Philadelphia, Pennsylvania

- Susan L. Jacobs
- Staff Attorney
- Legal Action Center
- New York, New York

- Marty Jessup, R.N., M.S.
- Assistant Clinical Professor
- School of Nursing
- Department of Family HealthCare Nursing
- University of California
- San Francisco, California

- Stephen R. Kandall, M.D.
- Chief
- Division of Neonatology
- Beth Israel Medical Center
- New York, New York

- Milton I. Lee, M.D.
- Associate Professor
- King-Drew Medical Center
- Department of Obstetrics and Gynecology
- Rancho Palos Verdes, California

- William H. Miller, Jr., M.D.
- Medical Director
- Kootenai Psychiatric Center
- Kootenai Medical Center
- Coeur d'Alene, Idaho

- Janet L. Mitchell, M.D., M.P.H.
- Chair, TIPs Project
- Chief of Perinatology
- Department of Obstetrics and Gynecology
- Harlem Hospital Center
- New York, New York

- Doug Modig
- Consultant
- Gathering of Eagles
- Bethel, Alaska

- Hon. Frances Pitts
- Presiding Judge
- Wayne County Probate Court
- Juvenile Division
- Detroit, Michigan

- Suzi Rodriguez, Ph.D.
- Director, Drug Abuse Programming
- AltaMed Health Services
- Los Angeles, California

- Jo-Anna L. Rorie, M.S.N., M.P.H.
- Director, Obstetrics and Gynecology Services
- Dimock Community Health Center
- Roxbury, Massachusetts

- Iris E. Smith, M.P.H.
- Director, Applied Research
- Human Genetics Laboratory
- Emory University School of Medicine
- Georgia Addiction, Pregnancy, and Parenting Project (GAPP)
- Atlanta, Georgia

- Beth Wasson
- Executive Director
- Triumph Treatment Services
- Yakima, Washington

- M. Lynn Yonekura, M.D.
- Chief, Division of Obstetrics
- Harbor UCLA Medical Center
- Torrance, California

Special Reviewers for the Consensus Panel
- Jamal Altwattar
- President
- Park DeWatt Medical Labs
- Northbrook, Illinois
- Catherine Cowell, Ph.D.
- Public Health Nutritional
- Consultant
- Maternal and Child Health Program
- Center for Population and Family Health
- Columbia University School of Public Health
- New York, New York
- Barry Zuckerman, M.D.
- Director
- Maternal and Child Health
- Boston City Hospital
- Boston, Massachusetts