# Chapter 3—Legal and Ethical Guidelines for the Care of Pregnant, Substance-Using Women

## Overview

Caring for pregnant, substance-using women and their infants can present complex legal and ethical issues concerning confiden- tiality, reporting, and the custody and protection of children. Service providers must understand and be prepared to address all aspects of these issues. To do so, they must be trained in the areas covered by these guidelines. This training should be developed at the Federal level and include examples that illustrate the applicability of the guidelines in a variety of environments.

The first level of training should be provided by the Federal Government to staff of State alcohol and other drug programs, maternal and child health agencies, child welfare offices, and child protective services agencies. Once trained, these staff will be better prepared to evaluate and recommend improvements to programs serving pregnant, substance-using women.

States, in turn, should offer training to local program staff. This training should inform service providers of new or clarified guidelines concerning the care of pregnant, substance-using women, and provide them with tools to use to document compliance with the guidelines.

An additional level of training should include those who interface with and are involved in the court process. Judges must be a priority target group for training, and attorneys, probation officers, and other court personnel should be encouraged to participate as well.

Training at all levels must be ongoing and updated at regular intervals to ensure that current information is available. Cross-training of health care professionals, child welfare specialists, and judges and attorneys involved in family law is highly desirable. New training funds are needed from the Federal level to ensure compliance with these guidelines.

### Scope of the Guidelines

The following guidelines address Federal and State confidentiality and reporting regulations, training in ethical and legal issues, and protective services for children.

The Consensus Panel believes that criminal penalties should not be imposed on women based solely on their use of alcohol and other drugs during pregnancy. In the event a substance-using woman is incarcerated or detained for a criminal offense, she should be given access to treatment services. Furthermore, pregnancy should never be the pretext for changing sentences given to women who commit crimes.

## Guideline 17—Confidentiality and Reporting

Jurisdictions may require that authorities be notified when an infant is born drug dependent or when an infant is exposed to alcohol and other drugs at the time of birth. When patient information is involved, treatment programs must follow Federal laws and regulations concerning the confidentiality of drug and alcohol treatment records. ^29^ State laws vary considerably, so overall national guidelines concerning confidentiality and the reporting of patient information are not possible. In circumstances where State laws are in conflict with Federal confidentiality regulations, the Federal regulations prevail.

29. Legal Action Center. Confidentiality: A Guide to the New Federal Regulations. New York: Legal Action Center, 1988.

All staff of alcohol and other drug treatment programs must be knowledgeable about Federal and State laws concerning confidentiality and patient records and how these laws affect their practices and the patients they serve. Treatment staff must be trained to understand and handle any conflicts between these laws and to recognize how such conflicts affect the delivery of services in their particular communities. Similarly, patients in alcohol and other drug treatment programs must be told about the extent of the confidentiality protection provided by law, and when this protection does not exist.

### Impact of Confidentiality and Reporting Laws on Women

State and local laws that require maternal alcohol and other drug use and fetal drug exposure to be reported to authorities have a significant impact on women and their children. These reports can be the impetus to remove children from their mothers' care and have them placed in protective custody or foster care. Knowing that such a report is in the offing, some women may forego their prenatal care or the follow- up services they need. The closer communities move toward measures that detain pregnant, substance-using women, the more punitive, detrimental, and potentially dangerous it becomes for these women and their children.

### Federal Regulations on Confidentiality of Alcohol and Other Drug Treatment Records

The following guidelines explain Federal regulations concerning the confidentiality of alcohol and other drug referral and treatment information.

#### Prohibition of Disclosure

The Federal confidentiality regulations prohibit disclosure of patient information as follows:

- Except under certain limited conditions, Federal confidentiality regulations prohibit the disclosure of records or other information concerning any patient in a federally assisted alcohol or drug abuse program. ^30^
  30. 42 CFR, sections 2.12-2.13(a)
- The prohibition on unauthorized disclosure applies whether or not the person seeking information already has the information, has other means of obtaining it, enjoys official status, has obtained a subpoena or warrant, or is authorized by State law. ^31^
  31. 42 CFR, sections 2.13(b)-2.20
- Any State provision that would permit or require a disclosure prohibited by the Federal rules is invalid. However, State laws may require greater confidentiality than the Federal regulations. ^32^
  32. 42 CFR, section 2.20
- Re-disclosure of patient-identifying information is prohibited unless such disclosure is made in compliance with Federal confidentiality regulations.

#### Exceptions to the Prohibition of Disclosure

Although the general rule is that patient-identifying information may not be disclosed, the regulations set out a number of conditions permitting limited disclosures with patient consent and a very few circumstances in which disclosures may be made without patient consent. Each of these conditions or circumstances has its own requirements and limitations. In general, permitted disclosures are those made as follows:

- With the written informed consent of the patient
- Pursuant to internal program communications
- Pursuant to a medical emergency
- In response to a court order following a court hearing in which disclosure is authorized
- Pursuant to a crime at the treatment program or against program personnel
- For research or audit purposes
- In the course of reporting child abuse
- Pursuant to a qualified service organization agreement
- In response to a request for nonpatient identifying information

### State Laws on Confidentiality of Alcohol and Other Drug Treatment Records

A variety of State confidentiality laws may affect how services are provided to pregnant, substance-using women. These laws may control the release of medical records; limit the ability of persons to testify in court based on information obtained when providing professional services (testimonial privilege); or prohibit disclosure of information regarding specific diseases, such as HIV and drug use. Service providers and alcohol and other drug treatment staff should consult with local counsel to determine which State confiden- tiality laws affect their practices, and develop protocols and training programs to help ensure that these laws are followed.

### Training on Confidentiality and Reporting

All individuals who provide services to pregnant, substance-abusing women must understand Federal regulations on confidentiality and receive training on State and local laws, regulations, and reporting requirements.

- Providers of health care and social services include, but are not limited to, physicians, social workers, nurses, psychologists, psychiatrists, child protective service workers, teachers, child care workers, and alcohol and other drug counselors.
- Providers of health care and social services must be trained to understand the differences among Federal, State, and local laws regarding confidentiality of information pertaining to alcohol and other drug treatment, medical care, mental health care, child abuse, and HIV/AIDS.
- Providers of health care and social services must know the relevant reporting laws pertaining to child abuse and neglect. This knowledge should include who is mandated to report child abuse and neglect, under what circumstances they are to report child abuse and neglect, and the penalty for not reporting such abuse and neglect.
- Programs serving pregnant, substance-using women are often part of community-based organizations or health care clinics. Staff of these programs must be aware of confidentiality laws and the right to informed consent as it relates to alcohol and other drug treatment.
- Cross-training concerning confidentiality and reporting must be given to individuals who may not understand relevant laws. This includes individuals involved in medical, legal, educational, alcohol, and other drug treatment, and social service fields.

#### Patient Records and the Courts

Service providers and pregnant, substance-using women should be concerned with how courts handle patient records and the circumstances under which courts can order medical and psychiatric evaluations.

- Once records go to adult court they become public record. Individuals concerned about court records and subpoenas need to understand the laws of their State. It should be noted that, in most but not all States, juvenile records are confidential.
- Courts can order an evaluation to determine if a woman needs treatment for alcohol and other drug abuse, to make a diagnosis, and to make a referral for treatment or services. This type of court-ordered evaluation, with the written informed consent of the woman, may be shared with those court officials involved in the disposition of her case.

#### Communicating With Patients About Confidentiality and Reporting

Providers of health care and social services should explain and discuss confidentiality and reporting laws with patients when they first seek care.

- The Federal confidentiality regulations require treatment programs to inform pregnant, substance-using women about their right to confidentiality, as well as their right to information about laws concerning reporting and court involvement.
- Pregnant, substance-using women should be informed by service providers about Federal, State, and local confidentiality and reporting laws, and how such laws will affect the delivery of services to them. Relevant areas of law may include the reporting of child abuse to appropriate authorities, custody consequences, and how courts may treat information contained in their records.
- No information that would identify a woman as an alcohol and other drug abuser or information from her treatment record may be disclosed to anyone outside the treatment facility without her written informed consent.
- When written informed consent is obtained, it must be time-limited, content-specific, and signed by the woman, in keeping with the requirements of the Federal confidentiality laws. A copy of the written informed consent document must be offered to the woman.

#### Confidentiality of Information on Infants and Children

A woman has the right to control the release of confidential records and information pertaining to her infant.

- In order to release confidential information, the written informed consent of the parent or legal guardian must be obtained.
- The written informed consent must meet all previously stated legal requirements controlling the release of confidential information.
- When a parent refuses to give consent, is incompetent to give consent, or cannot be found, the court may be requested to appoint a legal guardian for the child. This guardian is authorized to make medical decisions for the child, including the release of confidential information.
- Parental consent is not necessary when excused by law, which may vary by State. In many States, exceptions to blanket rules that require parental consent are made for medical emergencies and to report child abuse and neglect.

#### Unauthorized Release of Information

Nonconsensual and unauthorized release of confidential information may harm the child or mother and may subject the health care and social service provider to civil or criminal liability. To avoid this, agencies should develop protocols and procedures governing the release of information and train employees in their use. Agencies should also provide staff with access to counsel who are knowledgeable in the area of confidentiality. The following information, at a minimum, should be covered in protocols and training:

- Elements of and procedures for obtaining written informed consent
- Situations where consent for the release of information is not necessary
- Whether to notify the mother when information is permitted to be and is released without her consent
- How to respond to a request for information; for example, how to avoid responding in a manner that inadvertently and inappropriately confirms the existence of a medical or drug abuse condition
- How to limit disclosures to the information necessary and relevant for the provision of services to the mother or child, or to satisfy legal grounds for nonconsensual disclosure.

## Guideline 18—Child Protective Services

Child protective services agencies are mandated to help keep families together. Some women who enter alcohol and other drug treatment programs will be in contact with their local child protective services agency. These women may not view this involvement positively. In turn, many alcohol and other drug treatment programs find it difficult to deal with child custody and placement issues. As a result, some treatment programs exclude women who are or could potentially be involved with a child protective services agency. Until this circumstance changes, the doors to alcohol and other drug treatment will continue to close on pregnant, substance-using women -- the very women who need to be admitted.

Women should not be barred from treatment or discriminated against because they are pregnant. It must be recognized that the family circumstances for women may be fluid, rather than static. Children may be periodically absent and subsequently return to the home. Furthermore, alcohol and other drug use is a chronic relapsing disease. Relapse prevention must be an important part of any treatment approach.

Cross-service training of alcohol and other drug treatment staff and child protective services personnel should be supported. The aim of this joint training is to promote a better understanding of the issues common to both groups and to promote a strong working relationship between these service providers.

The following guidelines address intervention and assessment, placement of children in temporary foster homes, and development of permanent placement plans.

### Intervention and Assessment

#### Federal Laws

All health care and social service providers should be aware of the relevance of Public Law 96-272, the Child Welfare Act of 1980, for persons eligible for Aid to Families with Dependent Children (AFDC), as well as Public Law 95-608, the Indian Child Welfare Act of 1978, for Native American families. Responsible efforts should be made to keep children with the biological parents in their own home. When children are removed to temporary foster placement, reasonable efforts should be made to reunite the families.

#### State Laws

State laws should be understood as those laws that pertain to, build on, and are applicable to Public Law 96-272 and Public Law 95-608.

#### Agreements on Child Custody

When some women enter an alcohol and other drug treatment program, they will already have worked out an agreement about what must be done to keep their children. A treatment program should not discriminate against women on the basis of such agreements. However, women should also be informed of the legal risk they face with respect to program reporting policies. Information exchanged between the treatment program and child protective service agency must adhere to the guidelines on confidentiality.

#### Intervention With Children

If the child protective services worker, in attempting to work with the family, finds that the children may be at risk of imminent harm, then court intervention may become necessary (see Placement in a Temporary Foster Home below).

#### Anti-Discrimination Laws

Treatment programs must comply with other laws, such as the Americans With Disabilities Act and the Federal Rehabilitation Act of 1973, as amended. These laws prohibit discrimination in the use of public accommodations, including treatment programs.

### Placement in a Temporary Foster Home

#### Involvement of the Court

When a child remains at imminent risk of harm despite ongoing work with the family, the court may become involved.

The child protective services worker is usually mandated to involve the court if the child is at imminent risk of harm and intervention services have failed. Alcohol and other drug use alone, however, should not be the sole criteria for court intervention.

#### Court Placement Outside of the Home

After adjudication, if the court finds the child at imminent risk of harm, the child may be placed with a suitable relative or in a foster home. This placement outside of the home should not be made until all reasonable efforts have been undertaken to keep the family together.

### Development of a Permanent Placement Plan

#### Plans To Reunite the Family

When the child is removed from the home of the parent, the plan must be to return that child at the earliest possible date when it can be safely undertaken. To this end, reasonable ongoing efforts must be made to reunite the family as soon as possible.

#### Permanent Plans for Placement Away From Natural Parents

Under certain circumstances, the court may decide that the permanent plan will be placement away from the natural parent; this may occur after all reasonable efforts have been made to unite the family, when it is apparent that this unification cannot occur in the foreseeable future, and when such action is considered to be in the best interest of the child.