# Chapter 2—Medical Guidelines for Pregnant, Substance-Using Women

## Overview

Alcohol and other drug use during pregnancy can have detrimental effects -- both specific and nonspecific -- on the perinatal outcome. Specific effects of drug use can include facial dysmor- phology and organ system anomalies, such as alcohol- related birth defects. Pregnant women who use alcohol and other drugs are at an increased risk for preterm labor, thereby placing an already compromised fetus at increased risk. Nonspecific effects can include fetal growth retardation, resulting in small infants and decreased head circumference. ^20^

20. Hoegerman, G.; Wilson, C.A.; Thurmond, E.; and Schnoll, S.H. Drug-exposed neonates. The Western Journal of Medicine (Special Issue-Addiction Medicine) 152(5):559-564, 1990.

Substance-using women and their infants are endangered by the spread of the human immuno- deficiency virus (HIV). The number of women who are infected with the virus from shared needles and multiple sexual contacts, and the number of their infants who are infected through mother-to-infant transmission of the virus, is increasing at an alarming rate. ^21^ Every medical institution should follow Occu- pational Safety and Health Administration (OSHA) standards and universal precautions with respect to the blood and body fluids of all patients. To use such precautions only with known HIV-infected persons or known alcohol and other drug abusers places health care workers at great risk and fosters stereotyping.

21. American Public Health Association, AIDS Working Group. Pediatric HIV Infection. Washington, DC: APHA, 1989.

In this time of excessive use and abuse of alcohol, cigarettes, cocaine, and other drugs, it is clear that wider recognition of such abuse -- as well as active intervention efforts -- are needed. It is also clear that, in addition to the policies and procedures usually followed prenatally and during labor, delivery, and postpartum, specific attention must be paid to pregnant, substance-using women and their infants.

It is not enough to provide obstetrical care to substance-using women; a holistic approach is essential. This approach should incorporate alcohol and other drug treatment, as well as help for all of the problems of daily living and survival that confront and confound these women.

### Scope of the Guidelines

The following guidelines are designed to ensure that women receive the prenatal care, alcohol and other drug treatment, and comprehensive help they need to provide for their own health and that of their fetuses. In addition to obstetrical care, the guidelines address HIV-infected women, urine and/or blood toxicology, neonatal care, and nutrition.

## Guideline 8—Prenatal Intake

Procedures To Be Done During the First Prenatal Visit

1 Detailed health history, including alcohol and other drug use and psychosocial assessments

2 Comprehensive physical examination, focusing on the multiple medical problems of this population

3 Family psychosocial, medical, and alcohol and other drug use history

4 Health, psychosocial, and alcohol and other drug use history of the baby's father

5 Routine prenatal panel, plus other laboratory tests, including urine and/or blood toxicology screening, tuberculin test with an antigen panel, and baseline sonogram

6 Optional tests as needed, including screening for human T-cell lymphotropic virus (HTLV)-I and hepatitis C

7 Attention to areas of special concern in substance-using women

8 Attention to medical complications encountered in pregnancy

9 Referrals to an alcohol and other drug treatment program, nutritional counseling, social services, and other counseling

10 Additional referrals as needed

### Guidelines for the First Prenatal Visit

A number of significant environmental, psychosocial, and treatment considerations should be taken into account at the time of the woman's first prenatal visit. These considerations can affect the accurate assessment and successful engagement of the woman in ongoing prenatal care. They are as follows:

- Services should be provided in a supportive, culturally sensitive, and nonjudgmental environment by all health care personnel, from the receptionist to the physician.
- An assessment should be made of the woman's literacy and reading level. This assessment should include the woman who is functionally illiterate or has low literacy in her native tongue as well as in English. Literacy- and reading-level information will affect patient education efforts and the ability to obtain informed consent.
- The woman may enter prenatal care in different stages of pregnancy and from a variety of settings, including hospital emergency rooms, community health centers, family planning clinics, abortion clinics, or social service offices. It is essential to be able to offer assessment, triage, case coordination, and referral services from any or all of these settings.
- Case management services that coordinate the care of the pregnant, substance-using woman and her family are critical. Ideally, case conferences and referral to appropriate services should be managed by one health care professional who oversees the multidisciplinary team. An outreach worker who visits the woman in her home should be part of this team. The most difficult issue to resolve, given the financial and staffing constraints experienced by most health care and service providers, is the identification and designation of a case manager.
- Counseling about and obtaining of written informed consent for medical procedures and treatment are important. It is equally important to explain confidentiality, privacy, and other patient rights, as well as legal risks that may be posed by policies of the individual program.

The first prenatal visit should establish the components of the continuum of care that will extend through the woman's pregnancy and beyond. The visit should include the following components.

1Obtain a detailed health history. This history should cover legal and illegal drug use and last date of use; drugs used at the time of the first visit; medical history; current medications; psychosocial history, including emotional problems, mental illness, and housing and current living arrangements, with a special focus on the presence or lack of support systems; complete reproductive history, including current and past pregnancies, previous preterm deliveries, history of Caesarean sections, birth weight, number of therapeutic abortions, menstrual history, and methods of family planning; and sexual history, including previous sexually transmitted diseases.

2Conduct a comprehensive physical examination. This examination should be performed during the initial prenatal evaluation. It should include an evaluation of nutritional status, height, weight, and blood pressure, as well as an examination of the head, neck, breasts, heart, lungs, abdomen, pelvis, rectum, and extremities. Special attention should be given to those organ systems impacted by alcohol and other drug use, such as the liver in alcoholics and the skin in injection drug users. During the pelvic examination, attention should be given to the size of the uterus in relation to the presumed duration of the pregnancy.

3Obtain a family psychosocial, medical, and substance-using history. This history should cover alcohol and other drug use by all family members, diabetes, tuberculosis, cancer, heart disease (hypertension), congenital malformations, multiple births, and bleeding disorders. If any part of the history will have a significant impact on the course or outcome of the pregnancy, appropriate followup should be initiated. A visit to the woman's living environment should be an option.

4Obtain a health, psychosocial, and substance-using history for the infant's father. This history should cover legal and illegal drug use, alcohol and other drugs currently being used, medical history, and mental illness.

5 Complete a prenatal panel that includes

- Initial blood workup for all women that includes, but is not limited to
  - Blood group, Rh factor determination, and antibody screen
  - Rubella immune status and antibody titer measurement, unless previously documented
  - Serological tests for syphilis
  - Hepatitis B surface antigen screen
  - Complete blood count, including indices and platelets
  - Baseline liver function test
  - Baseline renal function test
- Other initial laboratory tests for all women that include, but are not limited to:
  - Cervical cytology (pap smear), unless the provider has results of a test performed within the last 3 months
  - Cervical culture for gonorrhea (optional culture for rectal and pharyngeal)
  - Chlamydia screen
- Hemoglobin electrophoresis as indicated
- Urine drug and/or blood screening (the selection of drugs for screening will vary by community and should be based on current local prevalence data).
- Human immunodeficiency virus (HIV) education and counseling. Offer antibody testing, with pre- and posttest counseling. Always obtain written informed consent that is consistent with the laws and regulations of the locale.
- Purified protein derivative of tuberculin (PPD) with antigen panel. If previously PPD-positive, a chest X-ray is recommended.
- Baseline sonogram. Level I scanning should be performed at a minimum to assess gestational age. Level II is recommended, especially when the gestational age is more than 18 weeks.

6Obtain optional tests. The benefit-to-cost ratio of these tests at the initial prenatal visit may vary depending on the population:

- Screening for human T-cell lymphotropic virus (HTLV)-I and hepatitis C; such screening is recommended, particularly in areas of high seroprevalence
- Diabetic screening as indicated
- Complete urine analysis with screening for infection
- Group B streptococcal (GBS) carriage cultures (rectal and introital)
- Maternal serum-alpha fetal protein (MS-AFP) as indicated (16 to 20 weeks gestation)
- Toxoplasmosis, cytomegalovirus, and herpes screening tests as indicated
- Electrocardiogram (EKG) as indicated

7Address areas of special concern. In the physical examination of pregnant, substance-using women, the following areas need special attention:

- Dermatologic: Presence of infections, abscesses, thrombosed veins, herpes infections, pyodermas, icterus, tattoos, bruising (as evidence of battering)
- Dental: Status of dental hygiene, existence of pyorrhea or abscessed cavities
- Otolaryngeal: Presence of rhinitis, excoriation of nasal septum
- Respiratory: Presence of wheezes, rales; signs of interstitial pulmonary disease
- Cardiovascular: Rate and rhythm abnormalities, presence of murmurs
- Gastrointestinal: Presence of hepatomegaly, scars from injuries, incisional or umbilical hernias
- Genitourinary: Presence of infections such as condyloma acuminatum, herpes vulvovaginitis, trichomonas vaginitis, bacterial vaginitis, and gonorrheal/chlamydial urethritis/cervicitis; condition of the uterus, including size configuration, fetal position, fetal heart rate, and fetal activity
- Breast: Nipples, evidence of trauma, "lumps or bumps," breast vein used for injection
- Musculoskeletal: Evidence of pitting edema, distortion of muscular landmarks due to subcutaneous abscesses, or brawny edema
- Lymphatic: Presence of lymphadenopathy and abscesses

8Address medical complications. Complications encountered in pregnancy that require special attention include

- Anemia
- Bacteremia/septicemia
- Cardiac disease, especially endocarditis
- Cellulitis
- Poor dental hygiene
- Edema
- Hepatitis, acute and chronic
- HIV infection
- Phlebitis
- Pneumonia
- Tetanus
- Tuberculosis
- Urinary tract infection, including cystitis, urethritis, and pyelonephritis
- Sexually transmitted diseases, including condyloma acuminatum, gonorrhea, herpes, syphilis, chlamydia, and other vulvovaginitides

9Provide referrals for all women that include

- Nutritional counseling
- Alcohol and other drug counseling
- Social services, including case management and possible home visitation
- Early intervention, including parenting education
- Educational and employment counseling

10Provide additional referrals, as indicated by the individual needs of the woman, that may include

- Genetic counseling
- Reproductive counseling and education about sterilization, contraceptive methods, abortion, adoption, and foster care planning. Explore the patient's knowledge of and feelings about the use of contraceptives, including cultural and religious issues and refusal and/or reluctance by the partner to use contraceptives.
- Childbirth and/or parenting classes as indicated
- Smoking cessation programs
- Mental health evaluation to rule out dual diagnosis (see Guideline 7 -Mental Health Considerations)
- Testing for mental capacity to rule out mental impairment due to alcohol and other drug use by the patient's mother
- Evaluation at infectious disease clinics for women who are HIV-infected. If they meet non-pregnant criteria for treatment with antivirals or prophylaxis, consideration should be given to initiating such treatment after careful discussion with the woman of known and unknown risks and benefits.

## Guideline 9—Prenatal Followup

Prenatal Followup Care for Pregnant, Substance-Using Women

1 Visits to identify and address medical and psychosocial problems, as well as health education considerations

2 Random urine and/or blood toxicologies

3 Encouragement to continue treatment and establish ongoing relationships with other service providers

4 Written release from the patient to enable service providers to exchange information

5 Discussion of reproductive options

6 Management of common complications

7 Encouragement to involve the father of the baby and other persons the woman considers significant, where appropriate

### Prenatal Followup Guidelines

1 Schedule visits to identify medical and psychosocial problems, as well as health education considerations. Prenatal followup visits should be determined by the woman's individual needs and risk assessment. Recognizing that the majority of substance-using women have high-risk pregnancies, it is desirable to see them every 2 to 3 weeks, up until 28 weeks, then weekly thereafter. It may not be necessary for all contacts to be with a physician; some contacts may be handled by a nurse or by the case manager. In some instances, a woman should be seen weekly throughout her pregnancy, particularly if she is not enrolled in a therapeutic alcohol and other drug treatment program. A woman with active medical or obstetric problems should be seen more frequently, at intervals to be determined by the nature and severity of her problems.

#### Up to 28 weeks

Up to 28 weeks, the following should be done at each visit:

- Measure weight and blood pressure; obtain urine dipstick for sugar, protein and ketones; test for nitrites and leukocyte esterase; obtain urine and/or blood toxicologies in accordance with the guidelines of the program.
- Assess for evidence of edema, abdominal pain, abnormal vaginal discharge, bleeding, headache, visual disturbances, nausea, vomiting, signs and symptoms of urinary tract infection, uterine contractions, pregnancy-induced hypertension, and common discomforts.
- Perform abdominal examination.
- Review the chart to compare weeks by date and weeks by examination.
- Auscultate fetal heart tones.
- Obtain sonograms as needed.
- Repeat blood work as needed.
- Provide for health education about the signs and symptoms of pregnancy, sexual intercourse, breast feeding, preterm labor precautions, common complaints of pregnancy, childbirth, and parenting.

#### From 28 to 34 weeks

From 28 to 34 weeks, in addition to the above, the following should be done when appropriate:

- Obtain diabetes screen.
- Administer RhoGAM, if indicated.
- Repeat blood work as needed (syphilis, complete blood count [CBC], antibody screen, repeat screens for gonorrhea and chlamydia, and HBsAg if initially negative).
- Repeat sonogram for growth or detection of other abnormalities.
- Initiate preterm labor precautions.
- Provide for antepartum testing, if indicated.
- Provide for health education and parenting considerations, including preterm labor precautions and early infant care.

#### From 35 weeks on

From 35 weeks on, the following should be done at each visit

- Repeat blood work as needed.
- Provide for antepartum fetal monitoring, if indicated.

2Obtain random urine and/or blood toxicologies. The purposes of these screens are to

- Establish the extent of recent alcohol and other drug use.
- Identify alcohol and other drug use and the need for early preventive interventions.
- Identify crises or coping difficulties in the woman.

For additional information and guidance, see Guideline 15 -- Urine Toxicology Considerations.

3 Encourage treatment and ongoing relationships with other service providers, including the patient's therapeutic alcohol and other drug program or support groups. Some patients need education and support to ready them for participation in a treatment program or support group, and to prepare them for change. Provide direct support or referral for pre-treatment intervention. If a patient is already involved in an alcohol and other drug treatment program or support group, establish a relationship with that provider after written informed consent is obtained from the patient.

- Methadone maintenance: Methadone maintenance has proved effective in the treatment of pregnant, opioid-dependent women. Participation in an alcohol and other drug treatment program is also important for those women using and abusing other drugs, such as alcohol, cocaine, amphetamines, benzodiazepines, cannabinoids, barbiturates, and hallucinogens.
- Service provider communication: It is important that the alcohol and other drug treatment provider and the prenatal health care provider have access to information about the progress of treatment in both disciplines.

4Obtain written release of information to enable service providers to exchange information. Release forms, giving permission for the exchange of infor- mation, must be signed by the patient in accordance with Federal confidentiality laws and regulations (see Chapter 3 -- Legal and Ethical Guidelines for the Care of Pregnant, Substance-Using Women). Multidisciplinary case conferences and communication between disciplines are essential. Meetings of the prenatal care provider, alcohol and other drug counselor, child protective service worker, probation officer, case manager, outreach worker, and social worker can help facilitate optimal prenatal care for the patient.

5Conduct an initial discussion of reproductive options. Beginning in the prenatal period, ethnically and culturally sensitive education on birth control and family planning should be provided and emphasized. Several routine methods of birth control are not optimal choices for the woman who uses alcohol and other drugs. An individual evaluation is required to determine the best methods for each patient. Condoms can be used in combination with other methods for birth control and for prevention of sexually transmitted diseases. Termination of pregnancy, adoption, and foster care are other options.

- Oral estrogen-progestin (contraceptive pill): Oral estrogen-progestin, preferably given in low doses, should be prescribed with care, as many substance- using women have vascular disease secondary to prolonged abuse of alcohol and other drugs. They also may not be conscientious in taking prescribed medication as indicated.
- Intrauterine devices (IUDs): These devices may be considered only if the patient's past history does not include pelvic infections. An additional complication with IUDs is the possibility of exposure to sexually transmitted diseases.
- Barriers: Barrier-type contraceptive methods, while the safest medically, are not the most effective and require consistent use. These methods include condoms -- which also reduce the risk for HIV and other sexually transmitted diseases -- and diaphragms.
- Subcutaneous implants: Norplant is an example of a long-acting, reversible contraceptive method.
- Sterilization: Permanent sterilization may be introduced as an option. The procedure can be completed before discharge postpartum.

The need for appropriate family planning must be stressed, because an unwanted pregnancy may add unnecessary anxiety to an already precarious situation. Counseling should be readily available and, at the discretion of the mother, should include significant others.

6Manage common complications. Some prenatal complications are sufficiently common among substance-using women to warrant specific comment. These complications include preterm labor, intrauterine growth retardation, hepatitis B, and HIV.

#### Preterm labor (PTL)

- Substance-using women are at risk to deliver prematurely. Pertinent risk factors for preterm delivery, aside from the use of alcohol and other drugs, include preterm and premature rupture of membranes, placental abruption, and stress.
- Due to the anesthetic/analgesic properties of most drugs of abuse, the patient may not perceive the early signs and symptoms of preterm labor and present too late to benefit from tocolytic therapy.
- Due to late initiation of prenatal care, it is sometimes difficult to distinguish true PTL from labor at term with a growth-retarded fetus.

#### Recommendations:

1. Substance-using patients should be educated about their increased risk for preterm labor. Preterm labor precautions should be reviewed at each prenatal visit, especially between the 26th and 36th week. These patients often confuse symptoms of PTL with those of drug withdrawal.
2. Screen for and treat infections that predispose to PTL, such as gonococcal or chlamydial infections.
3. Some patients may benefit from serial cervical exams and/or antepartum fetal heart rate/uterine activity testing to rule out PTL, especially if they have a multiple gestation or a previous history of PTL or preterm delivery (PTD).
4. A complete history of alcohol and other drug use and a urine and/or blood toxicology screen should be obtained on any patient presenting in PTL and/or with preterm and premature rupture of membranes.
5. Betamimetic tocolytics, such as ritodrine or terbutaline, should be used with great caution in stimulant-abusing patients. Alternative tocolytic agents, such as magnesium sulfate, may be preferable. ^22^
  22. Mitchell, J.L.; Tucker, J.; Loftman, P.O.; and Williams, S.B. "Preterm Labor Management of Substance Abusing Gravidas." Paper presented at the Office for Substance Abuse Prevention (OSAP) National Conference, Special Topic Peer Review Interdisciplinary Workshop, Washington, DC, July 14-15, 1992.
6. Assessment of fetal lung maturity may be helpful in distinguishing between PTL and labor at term with a growth-retarded fetus.

#### Intrauterine growth retardation (IUGR)

- The pregnancies of some substance-using women are complicated by IUGR. Pertinent risk factors for IUGR, aside from the synergistic effects of polydrug abuse, include congenital infections, congenital anomalies, multiple gestation, and poor nutrition.
- Since many of these patients present for prenatal care late in pregnancy, it is often difficult to distinguish between IUGR and poor estimation of dates. For this reason, serial scans for growth and weekly ante- partum fetal surveillance are often necessary.

#### Recommendations:

1. A complete history of alcohol and other drug use, and perhaps a random urine and/or blood toxicology screen, should be obtained on all patients with suspected or proven IUGR.
2. A complete nutritional assessment should be obtained on all these patients (see Guideline 16 -- Nutritional Considerations).
3. Screen for common congenital infections, including syphilis, human immunodeficiency virus (HIV), cytomegalovirus (CMV), and toxoplasmosis, as indicated.
4. A baseline sonogram and at least one followup scan 3 to 6 weeks later are recommended for all substance-using women. These procedures will rule out multiple gestation and major congenital anomalies, and document fetal growth. A level II-III scan for anomalies is helpful for all patients with documented IUGR.
5. Additional scans for growth and biweekly antepartum fetal surveillance (Non-Stress Test [NST] with Amniotic Fluid Index [AFI] or biophysical profile) are recommended for those patients with suspected or proven IUGR.

#### Hepatitis B

Studies indicate that some substance-using women are chronic carriers of hepatitis B (HBsAg-positive).

#### Recommendations:

1. Universal screening for HBsAg is recommended for all pregnant women at the time of their first prenatal visit.
2. In order to prevent the perinatal transmission of hepatitis B virus (HBV) to the newborn, HBV immunization of the baby must be initiated within 2 hours of delivery (hepatitis B immune globulin [HBIG] plus hepatitis B vaccine), with additional doses of vaccine at 1 and 6 months of age.
3. Due to the high prevalence of hepatitis B carriage among substance-using women, a history of current alcohol and other drug use by a patient presenting for delivery without results of HBsAg (i.e., if she had no prenatal care) necessitates initiation of the HBV immunization guidelines while awaiting results of HBsAg drawn at the time of admission.
4. Children and significant others of HBsAg-positive, substance-using women should also be assessed for hepatitis B carriage and vaccinated if they are HBsAg/HBsAb-negative.
5. Substance-using women who are HBsAg/HBsAb- negative are candidates for HBV immunization.

#### Human immunodeficiency virus (HIV) infection

See Guideline 13 -- Obstetrical Care for HIV-Infected Women.

7Encourage involvement of the father of the baby and other persons the woman considers significant. Involving persons whom the woman considers significant in her life can foster added trust in the program and facilitate discussion about reproductive choices. Their involvement can also provide insight into supports for and barriers to her sobriety.

## Guideline 10—Labor and Delivery for Women Who Have Received Prenatal Care

Procedures To Be Done During Labor and Delivery

Ideally, substance-using women have received prenatal care at some stage of their pregnancies. Procedures that are appropriate for their care during labor and delivery include

1 Detailed history, including recent alcohol and other drug use, and comprehensive physical examination

2 Repeat hepatitis B surface antigen and HIV screens, unless previously known to be positive, and repeat serological test for syphilis (titer if previously positive)

3 Complete urine and/or blood toxicology screen

4 Notification of pediatric and nursing staff providing primary care

5 Notification of social services

6 Fetal monitoring as indicated

7 Pain management as appropriate

8 Selection of the delivery method

9 Insertion of a central line for injection drug users, if necessary

10 Observance of universal precautions for blood and body fluids and OSHA standards

### Labor and Delivery Guidelines

1 Obtain a detailed history, including recent alcohol and other drug use, and conduct a comprehensive physical examination. The end of pregnancy is a period when women may relapse into previous substance- using behavior. Therefore, on admission to the labor room, a complete history and physical examination are needed. Information about alcohol and other drug use is important, as follows:

- Substance-using women often confuse the early signs of labor with signs of withdrawal, and they may medicate themselves during the early hours of labor.
- Substance-using women should be urged to admit all alcohol and other drugs taken recently. Once known, the effects of these drugs on the woman and her in- fant, and possible interactions with any medications used in labor, can be ascertained and the appropriate staff alerted.
- The use of alcohol or other drugs prior to arrival at the hospital can determine the type and amount of analgesic, if any, to be used during labor and delivery.

2 Repeat hepatitis B surface antigen and HIV screens, unless previously known to be positive, and repeat serological test for syphilis (titer if previously positive). Repeat these tests, with appropriate consents, to determine if there is any change from the previous tests, and to establish the present status of the woman and the fetus or neonate.

3 Obtain complete urine and/or blood toxicology screen. Substance-using women often arrive at the hospital with a high level of drugs in the blood due to recent use (see Guideline 15 -- Urine Toxicology Considerations).

4 Notify pediatric and nursing staff providing primary care. Advise staff of the patient's history of alcohol and other drug use, positive drug screening, and other pertinent medical conditions (e.g., results of hepatitis screen, serological test, and HIV test).

5 Notify social services. Advise staff of the patient's history of alcohol and other drug use and of any pertinent psychosocial concerns, such as unsafe living conditions.

6 Monitor the fetus as indicated. The greater likelihood of relapse at the time of labor increases the possibility of fetal stress and distress.

7 Provide pain management as appropriate. Analgesia and anesthesia administered during labor may include the same range of options available to all patients. Pain medication and attempts at adequate pain relief should never be withheld simply because the patient has a history of alcohol and other drug use. Regional anesthesia may be the procedure of choice. Analgesia and anesthesia administered during delivery may include

- Regional: Epidural or spinal
- Pudendal or local

The following statements also pertain:

- Due to tolerance, patients may require higher than usual doses of short-acting intramuscular/injection narcotics.
- Avoid use of combination narcotic agonist/ antagonists and pure narcotic antagonists because they may precipitate acute drug withdrawal.
- Methadone provides minimal analgesia for those women using opioids.

8 Select the delivery method dependent only on obstetrical indications.

9 Insert a central line if necessary. Because of the presence of sclerotic veins, many injection drug users require the insertion of a central line.

10 Follow universal precautions for blood and body fluids and OSHA standards that include

- Gowns, masks, eye protection, and double gloves for deliveries
- Gloves for invasive procedures, changing soiled linens or dressings, handling the placenta and cord, and handling the neonate prior to the first bath
- Mechanical or bulb aspiration of the newborn: Avoid mouth-operated aspiration traps.

## Guideline 11—Labor and Delivery for Women With No Prenatal Care

Procedures To Be Done During Labor and Delivery

Many substance-using women receive no prenatal care and are first seen by a health care provider during labor and delivery. Moreover, some women are in advanced labor or deliver prior to entering the hospital. Procedures for the care of these women include the following:

1 Detailed history, including alcohol and other drug use, and comprehensive physical examination

2 Complete baseline laboratory tests

3 Complete urine and/or blood toxicology screen

4 Sonogram for dating and to rule out multiple gestation

5 Notification of pediatric and nursing staff providing primary care

6 Notification of social services

7 Fetal monitoring as indicated

8 Pain management as appropriate

9 Selection of the delivery method

10 Insertion of a central line for injection drug users, if necessary

11 Observance of universal precautions for blood and body fluids and OSHA standards

### Labor and Delivery Guidelines

1Obtain a detailed history and conduct a comprehensive physical examination, although circumstances may impede these activities prior to delivery, that includes

- A complete medical, surgical, reproductive, and alcohol and other drug use history
- An appropriate family history, with special emphasis on alcohol and other drug use and mental illness
- Information about the baby's father, including alcohol and other drug use and medical history

2Obtain complete baseline laboratory data that include

- Blood group, Rh factor determination, and antibody screen
- Rubella immune status
- Serologic test for syphilis
- Hepatitis B surface antigen screen
- Liver function tests
- Renal function tests
- Complete blood count with indices and platelet count
- Complete urinalysis and urine screen for bacteriuria

HIV counseling should be provided in the postpartum period and testing should be encouraged.

If the patient is seen early in labor, it may be technically feasible to obtain a Pap smear, GC culture, and chlamydia screen. Do a PPD, preferably with an antigen panel unless previously positive, in which case a chest radiograph is needed.

3 Obtain a urine toxicology screen, with or without blood alcohol level, as indicated (see Guideline 15 -- Urine Toxicology Considerations).

4Obtain a sonogram. In order to decide about optimal delivery management, it is helpful to obtain a sonogram on intake prior to delivery. This procedure will provide information about approximate gestational age, estimated fetal weight (EFW), and presentation, and can rule out multiple gestation and major con- genital anomalies.

5Notify pediatric and nursery staff of the patient's history of alcohol and other drug use and other pertinent medical conditions.

6Notify social services so that a psychosocial assessment is completed after delivery. Because of confusion and fear, some substance-using women abandon their infants at the hospital rather than discuss various options for the infant's care and legal custody. Assignment of a case manager is essential for the patient and her newborn to ensure followup medical care, initiate alcohol and other drug treatment, and provide access to social services.

7Monitor the fetus as indicated. The greater likelihood of relapse at the time of labor increases the possibility of fetal stress and distress.

8Provide pain management. Follow the pain management procedures presented in Guideline 10 -- Labor and Delivery for Women Who Have Received Prenatal Care.

9Select the method of delivery dependent only on obstetrical indications.

10Insert a central line if necessary. Because of the presence of sclerotic veins, many injection drug users require the insertion of a central line.

11 Follow universal precautions for blood and body fluids and OSHA standards that include

- Gowns, masks, eye protection, and double gloves for deliveries
- Gloves for invasive procedures, changing soiled linens or dressings, handling the placenta and cord, and handling the neonate prior to the first bath
- Mechanical or bulb aspiration of the newborn: Avoid mouth-operated aspiration traps.

## Guideline 12—Postpartum Care

Procedures for the Postpartum Care of Substance-Using Women

1 Continuation of or enrollment in an alcohol and other drug treatment program

2 Use of an appropriate family planning method

3 Breastfeeding in methadone-maintained patients

4 Prevention and health maintenance efforts for the mother and infant

5 Child care and parenting education

6 Postpartum followup

### Guidelines for Postpartum Care

1Encourage continuation of or enrollment in an alcohol and other drug treatment program. The supportive involvement of the patient's significant others in her treatment should be encouraged. This involvement can be extremely important in the treatment of addiction and in positively influencing the environment in which the newborn will be raised.

2Encourage use of an appropriate family planning method. For further information, refer to the discussion of Preconception Counseling in the introduction to Chapter 1, Alcohol and Other Drug Treatment Guidelines for Pregnant, Substance-Using Women.

3 Permit breastfeeding in methadone-maintained patients. A number of substance-using women express a desire to breastfeed their infants. Breastfeeding is not contraindicated in a methadone-maintained patient if she is known to be free of other drug use and is known to be HIV-seronegative. If the mother is abusing multiple drugs that would expose the infant to diverse agents in varying levels, then breastfeeding may still be contraindicated. Breastfeeding is not recommended if the mother is HIV-infected.

4Initiate prevention and health maintenance efforts. The woman should be encouraged to start a preventive health maintenance program. This program should provide for immunizations and yearly checkups, including Pap smears and mammograms. For the infant, appropriate pediatric followup and referral to early intervention programs should be arranged.

5Provide child care and parenting education. Information should be provided on infant feeding, bathing, umbilical cord care, breastfeeding, appropriate approaches for "fussy" infants, and age-appropriate discipline for other siblings.

6Provide postpartum followup. The health care provider should meet with the woman 2 to 6 weeks after delivery to accomplish the following:

- Review the laboratory data.
- Review the care plan, including parenting education.
- Discuss the delivery and the well-being of the infant.
- Conduct a physical examination.
- Look for current alcohol and other drug use and perform screening.
- Encourage use of an appropriate family planning method.

## Guideline 13—Obstetrical Care for HIV-Infected Women

Procedures To Be Done With HIV-Infected Women

1 Initial workup

2 Medical treatment for HIV-related conditions

3 Obstetric management

### Obstetrical Care Guidelines for HIV-Infected Women ^23^ 23. Adapted from Women and Infants at Risk for HIV Infection: Guidelines and Protocols for Prevention and Care. San Francisco, CA: City and County of San Francisco Department of Public Health, Family Health Bureau Perinatal AIDS Project, n.d.

1Complete an initial workup. The initial workup should include a complete medical history, complete review of symptoms, comprehensive physical examination, and additional laboratory screening.

a) Complete medical history, with special attention to

- Sexual practices (sexual partners and their HIV status, practice of anal and oral sex, exchange of sex for money and drugs)
- Alcohol and other drug abuse (injection drug use, use of shared needles, drugs of choice, and sexual or drug partners' history of alcohol and other drug abuse)
- Blood transfusions, including dates and locations
- Tuberculosis (TB) exposure, past PPDs, and TB prophylaxis
- Sexually transmitted diseases (STDs), including herpes simplex genitalis/labialis, syphilis, genital warts, and chancroid
- Vaginal candidiasis
- Cervical dysplasia

b) Complete review of symptoms that includes

- Rashes, bruising, bleeding
- Fever, chills, night sweats
- Fatigue, exercise intolerance, dyspnea, cough
- Anorexia, nausea, vomiting, odynophagia, diarrhea
- Vaginal discharge, dysuria, abdominal pain
- Headache, visual changes, memory loss, depression, paresthesia, weakness
- Weight loss and/or poor weight gain prior to and during pregnancy

c) Comprehensive physical examination that includes:

- Vital signs: Temperature, weight, blood pressure, respiration
- Skin: Seborrheic dermatitis, folliculitis, track marks, purple lesions (Kaposi's sarcoma [KS] -- rare in women)
- HEENT: Fundi: cotton wool spots, retinitis (CMV), hemorrhages; and Mouth: ulcers (herpes, syphilis), hairy leukoplakia, thrush (candida), purple lesions (KS)
- Nodes: Lymphadenopathy
- Chest: Dullness, rales, rubs (PCP, TB, CMV), murmurs, gallops
- Abdomen: Hepatomegaly, splenomegaly
- Genital (include full pelvic and rectal exam): Ulcers (herpes, chancroid, syphilis), chancroid, condylomata (HPV, syphilis), discharge (candida, STDs), Pap smear (dysplasia)
- Neurological: Cognitive deficits, cranial nerve defects, sensory or motor changes, weakness (HIV, toxoplasma, cryptococcus)

d) Additional laboratory screening that includes

- HIV culture and antigen assay where available
- CBC, differential, platelets
- Immunological status assessment, e.g., CD- or T-cell counts
- Serological tests for syphilis, GC, chlamydia-repeat screening as indicated
- PPD with antigen panel
- Possible freezing of serum sample for later testing of titers for toxoplasma, CMV, and cryptococcus

2Provide medical treatment for HIV-related conditions. Medical treatment should be provided in consultation with HIV specialists and consistent with current recommendations. Women with CD4 counts of less than 200mm^3^ should be placed on an antiviral agent and given appropriate prophylaxis. ^24^

24. Sperling, R.S.; Stratton, P.; and the members of the Obstetric-Gynecologic Working Group of the AIDS Clinical Trials Group, National Institute of Allergy and Infectious Diseases. Treatment options for human immunodeficiency virus-infected pregnant women. American Journal of Obstetrics and Gynecology 79:443-448, 1991.

- Aggressively evaluate and promptly treat any conditions diagnosed.
- If laboratory studies indicate significant immuno-suppression, consider prophylactic treatment against opportunistic infections.
- Consider the use of an anti-viral agent (zidovudine [AZT]).
- Consider other experimental treatment guidelines and refer the patient as indicated.

3Provide obstetric management. Obstetric management should include all of the usual obstetric practices, with special attention to the following: a) Antepartum care

- Provide close prenatal followup.
- Obtain interim history and conduct a physical examination to include HIV-related elements.
- Repeat serological tests for syphilis, GC, chlamydia, and other laboratory tests as clinically indicated.
- Assess immunological status every trimester, or more often if the patient develops an illness or if a declining trend is noted.
- Perform a fetal assessment if clinically indicated. To prevent possible HIV transmission and nosocomial infection, avoid invasive procedures if possible, but not at the expense of accepted standards of care (e.g., genetic amniocentesis).
- Discuss with the patient the need to share pertinent medical information with her other direct care providers and those of her infant.
- Ensure primary care and specialized pediatric followup.
- Ensure involvement in an alcohol and other drug treatment program.
- Reinforce the need to practice safer sex.
- Recommend involvement in an HIV/AIDS support group.

b) Intrapartum care

- Follow universal precautions for blood and body fluids and OSHA standards that include
  - Gowns, masks, eye protection, and double gloves for deliveries
  - Gloves for invasive procedures, changing soiled linens or dressings, handling the placenta and cord, and handling the neonate prior to the first bath
  - Mechanical or bulb aspiration of the newborn: Avoid mouth-operated aspiration traps
- Utilize fetal monitoring as indicated.
- There is no specific indication for Caesarean delivery.

c) Postpartum care

- Breastfeeding is not recommended; otherwise, encourage mother-infant bonding.
- Ensure comprehensive medical followup for the woman, infant, and family members as indicated.
- Educate the woman to care for the infant's special needs.
- Ensure followup in an alcohol and other drug treatment program.
- Encourage use of an appropriate family planning method.

## Guideline 14—Drug-Exposed Neonates ^25^ 25. See Center for Substance Abuse Treatment. Drug-Exposed Infants Treatment Improvement Protocol (TIP). Rockville, MD: the Office, in press.

Effects on the Neonate From Maternal Use of Heroin, Methadone, and Cocaine

The following guidelines pertain to three substances that have a great impact on the health of infants -- heroin, methadone, and cocaine. Rapid recognition, careful assessment, and appropriate treatment of abstinence symptoms in infants exposed in utero to one or more of these substances will contribute to a satisfactory initial and long-term outcome for these neonates.

Programs dealing directly with drug-exposed neonates will find more detailed information on assessment and treatment in a protocol being developed by the Center for Substance Abuse Treatment. This detailed guideline is titled Drug-Exposed Infants Treatment Improvement Protocol (TIP)

### Neonatal Effects of Heroin

The effects of heroin on the neonate may include the following: 1Low birth weight. The low birth weight is due primarily to symmetric intrauterine growth retardation. In addition, low birth weight may be secondary to prematurity.

2Meconium aspiration. Meconium aspiration may be caused by hypoxia in association with antepartum or intrapartum passage of meconium secondary to fetal stress.

3Sexually transmitted diseases. Maternal lifestyle issues predispose the infant to congenital syphilis, gonorrhea, hepatitis B, and HIV infection.

4Neonatal abstinence syndrome. Neonatal ab-stinence syndrome occurs in about 60 to 80 percent of heroin-exposed infants. Its onset is usually within 72 hours of birth, with a high mortality if the syndrome is severe and untreated. Premature infants have been reported to show a less severe abstinence syndrome following opiate exposure. The syndrome involves the central and autonomic nervous systems, gastrointestinal system, and pul- monary system. Central nervous system (CNS) signs include irritability, hypertonia, hyperreflexia, abnormal suck, and poor feeding. Seizures are seen in 1 to 3 per- cent of infants. Gastrointestinal signs include diarrhea and vomiting. Respiratory signs include tachypnea, hyperpnea, and respiratory alkalosis. Autonomic signs include sneezing, yawning, lacrimation, sweating, and hyperpyrexia. If the infant is hypermetabolic, the postnatal weight loss may be excessive and subsequent weight gain suboptimal.

5Delayed effects. Delayed effects include subacute withdrawal with symptoms such as restlessness, agitation, irritability, and poor socialization that may persist for 4 to 6 months. There is an increased incidence of Sudden Infant Death Syndrome (SIDS). Behavioral and developmental consequences, such as hyperactivity and poor school performance, have been inconsistently reported. Studies on these behavioral and developmental consequences are difficult to interpret because of poor long-term followup and inability to control for postnatal environmental influences.

6No effect. It is important to understand that many infants will show no adverse effects from maternal use of heroin. Many women will know this, based on their own experience or that of other women. Providers should acknowledge this reality so that women will not use this knowledge to discount their advice.

### Treatment for Neonatal Effects of Heroin

Neonatal abstinence syndrome is best treated with a substitute opioid such as paregoric or with a CNS depressant such as phenobarbital.

### Neonatal Effects of Methadone

The effects of methadone on the neonate may include:

1Abstinence syndrome. The neonate suffers an abstinence syndrome similar to that seen with heroin. The abstinence syndrome for methadone usually starts later and lasts longer (due to longer half life) than for heroin. Central nervous system signs are prominent. Electroencephalograms (EEGs) are abnormal in about 50 percent of the infants. Seizures occur in about 7 percent of the infants, tend to occur between days 7 and 14, and are primarily myoclonic. Abstinence is more variable in onset and course than with heroin. Exposure to both heroin and methadone may produce a biphasic or atypical pattern of withdrawal.

2Fetal growth and reduced perinatal mortality. Multiple risk factors may contribute to poor fetal growth in methadone-exposed children. Although birth weight and head size may be reduced, fetal growth is generally more normal than with heroin, and may be related to the first trimester dosage of methadone. Reduced perinatal mortality compared with heroin use may be due to positive changes in lifestyle, including increased prenatal care.

3Postnatal effects. The postnatal weight change pattern may be suboptimal if the infant is hypermetabolic. A thrombocytosis may develop during the second week of life and peak at about the eighth week before returning to normal. There is biochemical evidence of hyperthyroidism in some infants.

4Breastfeeding. Breastfeeding is encouraged if the woman is HIV-seronegative and not abusing other drugs.

5Delayed effects. Delayed effects may include an increased incidence of SIDS. Long-term followup studies are incomplete and difficult to interpret. Generally, infants have performed within the normal range and no major neurologic or developmental disabilities have been reported.

6No effect.

### Treatment for Neonatal Effects of Methadone

Treatment with either paregoric or phenobarbital is effective.

### Neonatal Effects of Cocaine

The effects of cocaine on the neonate may include the following:

1Effects at birth. Generally, lower birth weights, head circumferences, and increased rates of prematurity have been reported compared to controls.

2No abstinence syndrome. There is no clinically documented neonatal abstinence syndrome for cocaine as is seen with the opioids.

3Neonatal dysfunction. Neonatal CNS dysfunction includes transient irritability, abnormal sleeping patterns, tremors, hypertonia, and lability of state. One study has reported that about 50 percent of the infants have abnormal EEGs in the neonatal period with reversion to normal within the first few months of life. Infrequent cerebral infarctions and seizures have been reported. Electroencephalographic abnormalities have been reported inconsistently. In addition, information on congenital malformation has been inconclusive.

4Breastfeeding. Most drugs pass through breast milk. The amount of cocaine that passes to the infant in the breast milk reinforces the neurotoxic syndrome.

5Delayed effects. Only preliminary long-term followup studies have been reported. A number of studies have suggested that incidence of SIDS is increased.

6No effect. It is important to understand that many infants will show no adverse effects from maternal use of cocaine. Many women will know this based on their own experience or that of other women. Providers should acknowledge this reality so that women will not use this knowledge to discount their advice.

### Treatment for Neonatal Effects of Cocaine

If treatment is indicated, a short course of phenobarbital is recommended. Use of the Brazelton Neonatal Behavioral Assessment Scale ^26^ is encouraged.

26. Brazelton, T.B. Neonatal Behavioral Assessment Scale. Philadelphia: Lippincott, 1975.

## Guideline 15—Urine Toxicology Considerations ^27^ 27. This section focuses on urine toxicology because this is the most widely used method of screening for most drugs. However, the most widely used method of detecting alcohol is through testing the blood or breath, although urine can be used. In discussing alcohol, this protocol therefore refers to blood and breath testing.

Considerations for Urine Toxicology

1 Specific urine toxicology techniques

2 Factors contributing to false-negative and false-positive test results

3 Approximate duration that drugs can be detected in urine

4 Alternate methods of screening for drug abuse

### Use of Urine Toxicology

Urine toxicologies are recommended for pregnant women in order to provide optimal, comprehensive medical care and alcohol and other drug treatment. They are, however, only an adjunct to good history-taking. The use of urine toxicology can reduce morbidity that may result from misdiagnosis and the subsequent use of inappropriate medications, such as betamimetic tocolytics for premature labor. The particular drugs for which a patient should be screened will depend on the specific geographic location and the substances most prevalent in that area.

Specific State laws may dictate approaches to the use of urine toxicologies. Test results in some States and localities are used for other than medical purposes and may have legal implications (see Chapter 3 -- Legal and Ethical Guidelines for the Care of Pregnant, Substance-Using Women).

A toxicology test that is positive for drugs and/or alcohol -- whether it is a "true" positive or a "false" positive -- may have extremely negative effects on women, such as criminal detention or possible loss of child custody. Because of this, the following guidelines recommend that urine drug testing be done only in cases where it is absolutely necessary. Since current urine toxicology techniques vary in their specificity (the extent to which they produce false-positive results), the Consensus Panel recommends that the alcohol and other drug abuse field adopt the standards used for urine drug testing in the workplace. These standards are contained in Mandatory Guidelines for Federal Workplace Drug Testing Programs, published in the Federal Register on April 11, 1988. Training in these new tests and procedures should be conducted for all pertinent personnel.

### Issues of Informed Consent

Important issues related to urine toxicology include the need to uphold the civil rights of the patient and to ensure that there is informed consent for the procedure. Testing a woman for illegal drugs in the absence of medical indications may be discriminatory, violate the woman's civil rights, and constitute an unlawful search and seizure. The woman has the right, whenever possible, to be informed of the risks, potential ramifications, and benefits of urine toxicology testing.

There may be times when informed consent cannot be obtained because of medical considerations. If urine is being tested for forensic rather than medical reasons, a separate consent should be obtained. Before testing neonates, informed consent should be obtained from the mother.

Successful treatment for alcohol and other drug abuse depends on a positive therapeutic relationship between the patient and her caregivers. Informed consent helps foster and is an integral part of a trusting and cooperative therapeutic relationship. Urine testing is just one of a variety of ways of identifying a woman who is in need of treatment services. Urine toxicology should never be the only reason for providing these services to a woman.

### Indications for Screening of Pregnant Women

Caregivers should ask questions regarding the use of alcohol, other drugs, and medications as a routine part of any medical history. Every effort should be made to identify which drugs are used; the frequency, pattern, and duration of use; last dosage; and the routes of administration. It should be made clear to the patient that this information is necessary for proper medical management of the following:

- Potential withdrawal, medical withdrawal, education, and alcohol and other drug treatment
- Physical manifestations attributable to alcohol and other drug use
- Potential interactions with other drugs or medications that may be given
- Fetal and neonatal effects

A urine and/or blood toxicology screen is necessary only in those circumstances where a history of drug use cannot be reliably obtained, as when a patient is comatose or confused, or when a discrepancy exists between the clinical findings and the drug thought to have been ingested. Caregivers should obtain informed consent and follow a closely monitored specimen collection procedure and chain of custody.

Reports indicate that a pregnant woman's race, ethnicity, and socioeconomic status have an overwhelming impact on whether or not she is screened. The following are indications used by some programs to screen a pregnant woman for drug use:

- History of alcohol and other drug use
- Loss of custody of other children
- No prenatal care
- Altered mental state (e.g., incoherent, unconscious, lethargic, combative)
- Preterm delivery; preterm labor; preterm, premature rupture of membranes
- Third trimester vaginal bleeding (e.g., placental abruption)
- Physical evidence of alcohol and other drug use (e.g., track marks)
- Signs and symptoms of intoxication or withdrawal

A pregnant woman who is known to be using drugs, whether through self-report or positive toxicology, should be treated for the acute medical condition and referred for alcohol and other drug treatment. In addition, a positive history of drug use or urine toxicology may suggest the need for a newborn toxicology screen, which may be ordered and obtained after delivery. In a newborn, a positive toxicology for nonprescribed drugs suggests that a social work evaluation be done.

### Testing Urine for Drugs

1Specific urine toxicology techniques. Drug tests are most commonly performed on urine, since most drugs and their breakdown products are excreted in the urine in higher concentrations than in the blood. While alcohol can be detected in the urine, testing of blood or breath is more widely used.

- Screening tests: These are rapid, sensitive tests that may be lacking somewhat in specificity (i.e., there may be false-positive results) and may require confirmatory testing.
  - Thin Layer Chromatography (TLC). TLC is a practical, economical, and sensitive method for detecting drugs in urine specimens. Examples of drugs detectable with TLC and acid hydrolysis include heroin (detected as morphine), morphine, amphetamines, barbiturates, codeine, cocaine, glutethimide (Doriden), methadone, methaqualone (Quaalude), phenothiazine, and quinine.
  - Immunoassay techniques. A variety of immunoassays and equipment are available to screen for drugs of abuse. Laboratories may use enzyme immunoassays (e.g., Enzyme Multiplied Immunoassay Technique [EMIT]), radioimmunoassays, and fluorescence polarization immunoassays. Examples of drugs detectable by immunoassays include opioids, amphetamines, cocaine metabolites, and phencyclidine (PCP).
- Confirmatory tests: These are highly specific tests (i.e., false-positive results are rare when the tests are performed correctly).
  - Gas Chromatography/Mass Spectrometry: GC/MS is an example of a confirmatory test that allows for quantitative analysis. Drugs detectable with GC/MS include opioids, amphetamines, cocaine metabolites, and phencyclidine, among others.

2Factors contributing to false-positive and false-negative test results. How samples are collected and handled is critical for avoiding false-positive and false-negative test results.

- Collecting samples: Improperly preparing the surfaces through which test materials are to be collected (e.g., using anesthetic lubricants for urinary catheters, cleansing skin with isopropyl alcohol) may cause false-positive results.
- Handling samples: Mislabeling, switching, and dilution of samples may occur prior to testing.

Intermittent injections and diluted urine can result in false-negative results. False-positive TLCs, although rare, may occur when spots of identical coloring and motility caused by different drugs are seen on the chromatograph. Legally prescribed cough medications may yield a positive TLC for morphine, since a portion of the codeine is transformed into morphine in the body. In addition, both false-negative and false-positive results can occur from certain foods a woman might ingest (e.g., poppy seeds).

If the patient has a bacterial urinary tract infection, a false-positive reaction with EMIT may occur with each test, indicating polydrug use. When there is an actual or potential urinary tract infection, the presence of lysoenzyme should be determined to rule out the possibility of a false-positive reaction. Finally, the expertise of the testing laboratory may determine the reliability of the results. Even the best laboratories have a relatively high incidence of nonreproducible results.

3Approximate duration that drugs can be detected in urine. The following table shows the approximate duration for detecting a number of drugs in the urine of non-pregnant adults. ^28^

28. Bean, X. Understanding toxicology reports, table 5. Eden Center Training Material. Los Angeles, CA: Charles R. Drew University, n.d.

Testing Urine for Drugs

Amphetamines | 48 hours
Alcohol | 12 hours
Barbiturates | 10 to 30 days
Valium (Diazepam) | 4 to 5 days
Cocaine | 24 to 72 hours
Heroin (detected as Morphine) | 24 hours
Marijuana | 3 to 30 days
Methaqualone (Quaaludes) | 4 to 24 days
Phencyclidine (PCP) | 3 to 10 days
Methadone | 3 days (depending on the dose)

Elimination times differ in neonates and adults. The elimination of certain fat-bound substances is unpredictable and may be enhanced by making the urine acidic. The length of time for detecting drugs in the urine depends to a great extent on dose and duration of use.

4Alternate methods of screening for drug use. Other methods of screening for prenatal use of drugs are not readily available and may not be acceptable in a court of law. They include

- Newborn meconium
- Radioimmunoassay of maternal hair

## Guideline 16—Nutritional Considerations

Considerations in Providing Nutritioin Services

1 Nutrition assessment services

2 Nutrition care plan

3 Nutrition counseling

4 Special areas of concern

### Possible Effects of Selected Substances on the Fetus

Alcohol and other drug use is often associated with poor nutrition. This association can result in serious health consequences for pregnant, substance-using women and their infants. Scarce financial resources and a lack of knowledge about the elements of good nutrition may further compound these effects. The following information describes the possible effects of maternal use of cigarettes, alcohol, marijuana, heroin, and cocaine. It is possible that infants will show no adverse effects from maternal use of these or other drugs. The use of other drugs in addition to those listed below, as well as polydrug use, may also impact the health of women and their infants. There are clinical recommendations for improved nutrition and guidelines for nutritional assessment and education.

#### Cigarette Smoking

Possible effects of maternal smoking during pregnancy. Decreased birth weight is the most consistently observed effect of maternal smoking on infants. This decrease in infant birth weight is on average 200 g. A recent review of the literature on the determinants of low birth weight has, like previous reviews, concluded that cigarette smoking is by far the single most important modifiable factor responsible for fetal growth retardation in developed countries.

Possible nutrition-related effects of smoking. Cigarette smoking may affect maternal nutrition and, consequently, fetal nutrition, in two important ways: (1) the increased metabolic rate in smokers can lead to lower availability of calories; and, (2) the exposure to tobacco may increase iron requirements and decrease the availability of certain nutrients such as vitamin B12, amino acids, vitamin C, folate, and zinc. In smokers, uteroplacental blood flow restricts nutrient and oxygen flow to the fetus.

#### Alcohol

Possible effects of excessive maternal alcohol consumption during pregnancy. Alcohol is now recognized as a potent teratogen. Infants of mothers who consume excessive amounts of alcohol during pregnancy may suffer from Fetal Alcohol Syndrome or Fetal Alcohol Effects (see Guideline 3 -- Medical Withdrawal From Alcohol for more information).

Possible nutrition-related effects of alcohol consumption. Alcohol consumption may be related to decreased dietary intake, impaired metabolism and absorption of nutrients, and altered nutrient activation and utilization. Interactions between alcohol and deficiencies of such nutrients as protein and zinc may also play a role in the etiology of alcohol-related effects on the fetus.

Although there is no convincing evidence that nutritional supplementation will counteract the adverse effects of alcohol, standard prenatal vitamins plus folate, B12, and iron supplementation should be prescribed. However, since alcohol abuse has clearly been shown to be detrimental to the fetus, nutritional supplementation should not replace efforts to encourage women to limit or eliminate alcohol intake during pregnancy.

#### Marijuana

The marijuana of the 1990s is very different from the drug that was available in the 1960s. Today there is more THC (tetrahydrocannabinol) in marijuana because of plant hybridization.

Possible effects of maternal marijuana use during pregnancy. Decreased birth weight and body length are the most commonly noted effects among infants of mothers who use marijuana during pregnancy.

Possible nutrition-related effects of marijuana use. There are conflicting study results on the possible nutrition-related effects of marijuana use. Some studies indicate weight gain by infants, other studies show less weight gain, while still others show no difference between infants whose mothers used marijuana and infants whose mothers did not use the drug.

#### Heroin

Possible effects of maternal use of heroin during pregnancy. Decreased birth weight, prematurity, and intrauterine growth retardation are among the effects on the fetus of maternal heroin use during pregnancy. Medical complications from the use of dirty needles may also ensue, such as abscesses, bacterial endocarditis, and hepatitis (see Guideline 4 -- Opioid Stabilization for more information).

Possible nutrition-related effects of heroin use. These effects include poor nourishment, with vitamin deficiencies, iron deficiency anemia, and folic acid deficiency anemia. Many of the effects on pregnancy and the fetus can be mitigated in a comprehensive methadone maintenance treatment program.

#### Cocaine

Possible effects of maternal use of cocaine during pregnancy. Spontaneous abortion, intrauterine growth retardation, premature labor, and abruptio placentae are among the effects of maternal use of cocaine. Information on the congenital effects of maternal cocaine use are inconclusive (see Guideline 5 -- Cocaine Withdrawal for more information).

Possible nutrition-related effects of cocaine use. As is true for marijuana, little is known about the nutrition-related effects of cocaine use. Cocaine's vasoconstrictive ability may lead to fetal hypoxia and reduced nutritional supply to the fetus. Since cocaine, like amphetamines, acts as an appetite suppressant, an inadequate maternal diet may play a role in retarding growth in fetuses of cocaine abusers.

### Clinical Recommendations

Prevention and intervention. The highest priority should be given to efforts to prevent or stop alcohol and other drug use by pregnant women. There is clear evidence that cigarette smoking and alcohol and other drug use adversely affect the health of the mother and fetus.

Nutrition counseling and intervention. Since nutritional deficiencies can be expected, especially among heavy abusers of alcohol and other drugs, diet counseling, referral to a social worker, and other intervention strategies to improve food intake are recommended.

Multivitamin-mineral supplementation. Because heavy abusers of alcohol and other drugs may have difficulty in taking the steps needed to improve their dietary intake, the use of multivitamin-mineral supplements is recommended.

### Nutritional Assessment and Education Guidelines

More than 40 different nutrients are needed for good health. Essential nutrients are the amino acids from protein, vitamins, minerals, fatty acids, and calories obtained from carbohydrates, protein, and fat. Since no single food supplies all these nutrients in the amounts needed, it is recommended that women eat a variety of nourishing food daily. To plan meals and snacks, foods are divided into five groups: (1) vegetables; (2) fruits; (3) breads, cereals, rice, and pasta; (4) milk, yogurt, cheese, and other dairy products; and (5) poultry, fish, lean meat, dry beans and peas, eggs, and nuts.

The 1990 edition of the Dietary Guidelines for Americans recommends the following:

- Eat a variety of foods
- Maintain healthy weight
- Choose a diet low in fat, saturated fat, and cholesterol
- Choose a diet with plenty of vegetables, fruits, and grain products
- Use sugar only in moderation
- Use salt and sodium in moderation

1Provide nutrition assessment services for all patients to identify and assess for

- Nutritional high-risk status
- Probable food deficiencies
- Probable food excesses
- Interest in breastfeeding
- Eligibility and certification for food supplement programs such as Women, Infants, and Children (WIC) and Food Stamps. If the woman has children, include school breakfast and lunch programs, summer feeding programs, and child care food programs.
- Smoking status
- Lactose intolerance
- Underlying eating disorder. It is not uncommon for substance-abusing women to have an underlying eating disorder -- a possibility that needs to be considered as a woman stops using drugs and<%-9>/or alcohol. Appropriate referrals for additional counseling may be needed.

2Develop a nutrition care plan that describes the nature of the diet and counseling needs of the patient.

3 Provide nutrition counseling to

- Teach about the appropriate diet, taking into account the patient's cultural food patterns, access to food, and lifestyle.
- Teach management of the food budget and meal planning as needed.
- Explain the WIC Program and other federally funded food assistance and nutrition programs.
- Provide nutrition education.
- Make referrals for smoking cessation counseling, as indicated.

4Address special areas of concern. All patients should receive instruction and assistance regarding the following:

#### Poor diet pattern

- Encourage the patient to eat nutritious foods as snacks, since these provide an important source of nutrients for a woman who does not eat three meals a day.
- Educate the patient on nutritious snacks, which may include, but are not limited to milk, cheese, yogurt, crackers, popcorn, fruit, carrot sticks, and leftover meat.

#### Poor quality diet and eating problems

- Instruct the patient on recommended servings of each food group and reinforce healthy choices, including foods that are culturally acceptable and are a part of the woman's diet.
- Recommend a decrease in "empty-calorie" (high in calories and lacking or low in essential nutrients) and high-fat foods.
- Recommend a decrease in or avoidance of stimulants such as caffeine (e.g., coffee, tea, and chocolate).

#### Underweight

- Assess the patient's attitude toward weight gain and obtain a past and current history of eating disorders. Assess for tobacco intake and encourage the patient to decrease use. Encourage the patient to discontinue stimulants such as cocaine that inhibit weight gain.
- Assess the patient's appetite, looking for
  - Poor appetite as a result of stress. A patient may need to have major stress factors handled before her underweight status can be successfully resolved.
  - Poor appetite as a symptom of protein, calorie, vitamin B, or vitamin C deficiency. A multivitamin supplement should be provided.
- Make dietary recommendations that include
  - A basic diet. The basic diet should include at least all recommended servings from each of the five food groups.
  - Additions to the basic diet. Additional food from any of the five food groups should be added to the diet.
  - High-density foods. Nutritious, high-density foods should be added as part of the diet (e.g., pizza, cheese, peanut butter, ice cream, and whole milk).
  - An eating schedule. The underweight patient should be encouraged to eat frequently throughout the day, with a goal of five to six feedings.

#### Overweight

- Assess the patient's attitude about being overweight and discuss with the patient ways to
  - Follow the five food group plan of eating, dividing the plan into at least three meals and two snacks.
  - Increase intake of fresh fruits and vegetables, whole-grain cereals, and dried beans.
  - Eliminate or decrease intake of "empty-calorie" food.
  - Decrease fat intake.
  - Avoid fad diets.
  - Review the patient's family history of diabetes and her diabetes screen during pregnancy.
  - Encourage the patient to increase moderate exercise, such as walking and other non-weight-bearing forms of exercise. Increased exercise is at least as important as dietary changes in weight maintenance.
  - Discuss goals. For an overweight patient, the goal is weight maintenance and minimal weight gain. Weight loss is discouraged. Periodic evaluation of urine ketones is a helpful monitoring method.
  - Follow up as necessary.

#### Potential vitamin deficiency

- Assess the patient's methods of preparing foods to uncover potential vitamin deficiencies caused by the preparation process.
- Determine the possible need for specific multivitamin supplements.
- Follow up as necessary.