# Chapter 1—Alcohol and Other Drug Treatment Guidelines for Pregnant, Substance-Using Women

## Overview

Traditionally, alcohol and other drug treatment programs served adult males, and few women received the treatment they needed. The scarcity of treatment services for women continues today. It is imperative that programs include services designed specifically for women, particularly pregnant women.

Many alcohol and other drug treatment programs do not accept pregnant women because of liability issues or a lack of knowledge about pregnancy. Furthermore, programs have not had access to standardized guidelines for treatment, case management, and followup services. The information that follows offers such guidance and is intended to encourage programs to broaden and strengthen their services to pregnant, substance-using women.

### Profile of the Women Being Served

Reliable national estimates of the prevalence of alcohol and other drug use by pregnant women are not available. Several factors limit the accuracy and usefulness of current estimates, including differences in the populations studied, the lack of representativeness of samples used, and differences in the methods employed to determine drug use. Results of specific studies, such as those reported below, illustrate to some degree the nature and extent of the problem.

- Data from one study of 36 hospitals, mainly in urban areas, were extrapolated to arrive at an estimate of 375,000 infants exposed in utero to illegal drugs each year, or 11 percent of all births. ^5^
  5. Freier, M.C.; Griffith, D.R.; and Chasnoff, I.J. In utero drug exposure: Developmental follow-up and maternal-infant interaction. Seminars in Perinatology 15(4):310-316, 1991.
- A study conducted in Pinellas County, Florida, of urine samples from more than 700 women enrolling in prenatal care during a 1-month period in 1989 found little difference in the prevalence of drug and alcohol use between women seen at public clinics (16.3 percent) and those seen at private offices (13.1 percent), as well as similar rates of substance abuse among white women (15.4 percent) and black women (14.1 percent). ^6^
  6. Chasnoff, I.J.; Landress, H.J.; and Barrett, M.E. The prevalence of illicit drug or alcohol use during pregnancy and discrepancies in mandatory reporting in Pinellas County, Florida. New England Journal of Medicine 322:1202-1206, 1990.
- A study based on a review of medical records in eight hospitals in Philadelphia in 1989 found that 16.3 percent of women had used cocaine while pregnant. ^7^
  7. Hurt, H. 1000 Babies: Philadelphia 1989 (abstract). Pediatric Research 27:93a, 1990.
- A study that assessed drug use, utilizing urine samples obtained at admission for delivery in all seven hospitals in Rhode Island, showed that 3 percent of women used marijuana. ^8^
  8. Centers for Disease Control. Statewide prevalence of illicit drug use by pregnant women -- Rhode Island. MMWR 39:225-227, 1990.
- Fifty-nine percent of the women in a Boston City Hospital study acknowledged that they had consumed alcohol during their pregnancies. ^9^
  9. Frank, D.A.; Zuckerman, B.S.; Amaro, H.; et al. Cocaine use during pregnancy: Prevalence and correlates. Pediatrics 82:888-895, 1988.

To meet the need for estimates of the prevalence of alcohol and other drug use by pregnant women that are generalizable to the Nation, the National Institute on Drug Abuse has recently sponsored a national, hospital-based study known as the National Pregnancy and Health Survey. Until these and other data become available, service providers should be alert to patterns of alcohol and other drug use occurring locally among women of all socioeconomic and ethnic groups.

Those with clinical experience in treating substance-using women have found that the therapeutic needs of women, especially those with children, are markedly different from the needs of men. Substance-using women come from every ethnic and socioeconomic group and have a multitude of needs. Moreover, a substantial portion of the women who seek publicly supported treatment for their addictions share a core group of problems that reflect problems of the communities in which they live. Unless these core problems are addressed, women will be unable to take full advantage of the therapeutic process.

Many women who seek treatment for their alcohol and other drug problems through publicly funded programs share the following characteristics:

- Function as single parents and receive little or no financial support from the birth fathers
- Lack employment skills and education and are unemployed or underemployed
- Live in unstable or unsafe environments, including households where others use alcohol and other drugs. Many women are at risk of being homeless and some are homeless.
- Lack transportation and face extreme difficulty getting to and from a variety of appointments, including treatment
- Lack child care and baby-sitting options and are unable to enroll in treatment
- Experience special therapeutic needs, including problems with codependency, incest, abuse, victimization, sexuality, and relationships involving significant others
- Experience special medical needs, including gynecological problems

### Gender-Specific Alcohol and Other Drug Treatment

Alcohol and other drug treatment providers need to understand and address the specific problems pregnant, substance-using women face in accessing and participating in treatment. Treatment programs may lack linkages to medical services, especially prenatal care. Similarly, providers of prenatal care have a poor understanding of addiction and treatment issues and may not have appropriate linkages with alcohol and other drug treatment providers. Both prenatal and drug treatment providers have a poor understanding of treatment issues specific to women.

It is recommended that treatment programs serving pregnant, substance-using women include the following services, or support active outreach to and linkage with appropriate service resources already available in the community:

- Comprehensive inpatient and outpatient treatment on demand
- Comprehensive medical services
- Gender-specific services that are also ethnically and culturally sensitive. These services must respond to women's needs regarding reproductive health, sexuality, relationships, and all forms of victimization. Services should be offered in a nonjudgmental manner and in a supportive environment.
- Transportation services, including cab vouchers, bus tokens, and alternatives for women who live in communities where public transportation is cumbersome, unreliable, or unsafe
- Child care, baby-sitting, and therapeutic day care services for children
- Counseling services, including individual, group, and family therapy
- Vocational and educational services leading to training for meaningful employment, the General Equivalency Diploma (GED), and higher education
- Drug-free, safe housing
- Financial support services
- Case management services
- Pediatric followup and early intervention services
- Services that recognize the unique needs of pregnant, adolescent substance-users

In addition to the delivery of direct services, there is a need for continuing collaborative efforts by maternal and child health programs, primary health care agencies, mental health agencies, and alcohol and other drug programs. Such collaboration can be useful in conducting needs assessments, designing interdisciplinary strategies, and establishing linkages through memoranda of understanding and interagency agreements.

Ongoing technical assistance and training is recommended for all health care, alcohol and other drug treatment, and other social service providers. Such efforts must involve administrative staff as well as direct service personnel to ensure that supportive, appropriate, and comprehensive care is offered to pregnant, substance-using women.

### Preconception Counseling

All women who receive alcohol and other drug treatment services should receive counseling on the full range of reproductive options, including preconception counseling. Issues that should be thoroughly discussed include

- The various methods of contraception and the attitudes of the woman, her significant others, and her community regarding their use
- The impact on the woman and the fetus of alcohol and other drug use during pregnancy
- The teratogenic impact of prescribed medications, such as Antabuse and various anticonvulsants
- Alternative medications with reduced or no teratogenic potential for such common problems as seizure disorder. An obstetrician or geneticist can recommend such medications.

For patients who temporarily require medications such as Antabuse, or for those who choose to postpone childbearing, an effective, reversible form of contraception should be recommended. Substance-using women who have a history of irregular menses and involuntary infertility should be warned that sobriety or the successful initiation of a recovery program may result in a resumption of ovulation and an increased risk for unplanned pregnancy.

### Access to Services

Pregnant, substance-using women may access health care services from a variety of sites, including emergency rooms, pregnancy testing sites, clinics treating sexually transmitted diseases, community health centers, and clinics of the Special Supplemental Food Program for Women, Infants, and Children (WIC). Occasionally, alcohol and other drug treatment program staff are the first to notice that a woman is pregnant. Regardless of where she accesses care, appropriate referrals for prenatal care should be provided, and she should be assisted to follow through on these referrals. The two perforated charts that accompany this TIP as Appendix I illustrate the components of comprehensive health care, depending on whether the woman's point of entry into the treatment system is alcohol and other drug treatment or prenatal care.

Access to care must be simplified for a woman when she enters the system. She should receive whatever support is needed -- whether it is financial assistance, help in setting up appointments, or transportation and child care services. Whenever possible, a case manager should schedule a specific prenatal appointment for the woman and initiate other needed services. In addition, a psychiatric assessment should be done to identify cases of alcohol and other drug use and psychiatric illness.

It may be difficult to convince a pregnant, substance-using woman to seek prenatal care. The concept of preventive health care, as opposed to emergency-necessitated health care, may be a foreign concept to her. More importantly, she may have a basic distrust or dislike of the health care system in general, and doctors in particular. Her feelings of fear and guilt, and possible negative past experiences, may cause her to expect poor treatment. Sometimes she provokes a hostile interchange with health care professionals.

Women need to receive health care services in an environment that is nonjudgmental, nonpunitive, nurturing, and culturally and linguistically sensitive. It is essential for all members of the health care team, from the clerical staff to the physicians, to recognize the importance of providing prenatal, postnatal, and pediatric services in a caring way. Staff must avoid comments designed to make the patient feel guilty or ashamed, such as the use of pejorative words like "wino" or "junkie." Each health care visit is an opportunity to provide positive reinforcement to the substance-using patient.

### Scope of the Guidelines

These alcohol and other drug treatment guidelines discuss the continuum of care and the central role of case management that are essential for the delivery of comprehensive services to pregnant, substance-using women and their families. Medical stabilization and withdrawal guidelines establish a basis for alcohol and other drug treatment. Specific guidelines cover alcohol, opioids, cocaine, and sedative-hypnotic drugs. A review of mental health considerations in treating pregnant, substance-using women completes the chapter.

## Guideline 1—Continuum of Care

The pregnant, substance-using woman requires a continuum of care that includes a broad range of support services provided over an extended period of time. This continuum of care should reflect the complexity of her multiple roles as a person in recovery, parent, partner, and frequently, single head of a household. Ideally, support services should be provided as long as the woman and her family need and can benefit from them, potentially until her last child reaches adulthood. In reality, support services may be available for a period of a few months to several years.

The case management function is essential for the recovery and well-being of the substance-using woman and her family. Virtually any agency can provide case management services, although the lead agency typically assigns an appropriate staff person to this role, such as a social worker or nurse. The case manager assists the patient in accessing services, and monitors her participation and progress in using health care, alcohol and other drug treatment, and other social services.

The multiple services coordinated by the case manager are generally provided by a variety of agencies. Many of these services are initiated during or even prior to pregnancy and should continue after delivery for as long as they are appropriate. The consortium of service providers may change over time, depending on the family's individual circumstances and resources.

The case manager should be aware that differences in philosophies may exist between health and social service agencies and the alcohol and other drug treatment field. Behaviors that health and social service agencies view as helping and supportive are often viewed as codependent behaviors by the treatment field. As agencies work together on behalf of patients, they too must recognize and handle complex and legitimate differences in philosophies and practices.

### Case Management

Case management is a vital function that helps to ensure that patients receive and appropriately utilize a variety of services necessary for their improved functioning. Case management should be initiated prenatally and continue throughout the postpartum period for all substance-using women. Services should be provided and maintained as appropriate for the individual woman and her family. The case manager should support and guide the patient to address issues concerning her recovery from alcohol and other drug abuse, develop psychosocial and parenting skills, and meet her survival needs. Key case management functions include

1A review and assessment covering

- Physical and mental health history
- Psychosocial status, including family history, parenting skills and knowledge, and potential parenting problems (e.g., a history of sexual abuse)
- Alcohol and other drug use, treatment, and recovery status
- Support systems available to and used by the family, including sources of primary and emergency care
- Nutritional status of the mother and fetus
- Status of any unresolved legal issues, including outstanding warrants, domestic violence, child custody, adoption, foster care, and divorce
- Environmental circumstances, including financial status and needs, condition of housing, and availability of transportation
- Educational and vocational competencies
- Involvement with other social service agencies

2An individual care plan prepared in conjunction with the patient and other service providers. This plan should address, at a minimum, the areas listed above. It may also cover arrangements for infant case management, either directly or through referral.

3Discussion of the plan with the patient and other members of her health care and service delivery team. After agreement is reached on the individual plan, the case manager should schedule the needed services.

4Referrals to other agencies, groups, or institutions as needed. These referral linkages should be made in conjunction with plans for ongoing communication about the patient's status.

5Monitoring of the patient's progress in the programs in which she is enrolled, with followup contacts made if she fails to participate as planned and scheduled.

6Ongoing case management support at regularly scheduled intervals, with termination ideally agreed upon by the patient and the case manager. Standards of success should be determined on an individual basis, but should allow a period of time for the patient to become adjusted to her drug-free status, to achieve self-sufficiency, and to feel confident about her parenting skills.

7A review of the patient's individual care plan with revisions as needed during the recovery process

### Comprehensive Service Delivery

The delivery of comprehensive services to substance-using women and their families should continue postpartum. The greatest success is achieved by and for these women when a continuum of care is available to address their special needs as women, mothers, spouses, and heads of households. The following services are often needed: 1Health Care Services

- Comprehensive, high-risk obstetrical care
- HIV antibody counseling and testing
- Routine checkups and immunizations for all children through a well-baby clinic, care by a pediatrician or other physician for specific health concerns as long as needed, and referral to early intervention programs
- Postpartum medical and dental checkups for the mother as long as needed
- Family planning, including contraceptive counseling and contraceptives
- Counseling for postpartum depression and for guilt about the effects of prenatal drug use on the infant, as needed
- Health care for other family members

2Alcohol and Other Drug Treatment Services

- Medical withdrawal, ^10^ as needed, in collaboration with prenatal care providers
  10. This report uses the term medical withdrawal and not detoxification to more accurately reflect the actual process that occurs under medical observation.
- Ongoing alcohol and other drug treatment through a program of methadone maintenance, outpatient treatment, day treatment, or intensive outpatient care; or through intermediate or long-term residential care that provides services to a patient's children during the inpatient period
- Alcohol and other drug treatment in gender-specific programs that are ethnically and culturally sensitive, whenever possible
- Continuing support and relapse prevention through accessible community groups, including Alcoholics Anonymous (AA), Narcotics Anonymous (NA), Adult Children of Alcoholics (ACoA), Talking Circles, and community and church support groups, with the understanding that relapse should not exclude women from treatment
- Group and individual counseling, focusing on such areas as codependency, self-esteem, and issues of sexuality, parenting, and relapse prevention

3Survival-Related Services

- Housing assistance to find drug-free, affordable family housing, emergency shelters, safe homes
- Financial assistance through Medicaid and Aid to Families with Dependent Children (AFDC), as well as food from programs such as the Special Supplemental Food Program for Women, Infants, and Children (WIC), if eligible
- Vocational and job skills training with child care and/or transportation services
- Child care that is affordable and appropriate for the safety and well-being of the child. Programs should encourage the creation of and access to therapeutic and developmental child care centers onsite and in the community.
- Transportation for medical care, alcohol and other drug treatment, and for child care, and for vocational, parenting, homemaking, and recreational activities
- Home management training to develop nutrition, budgeting, time management, and food preparation skills
- Legal services for such issues as domestic violence, child custody, adoption, and divorce

4Psychosocial Services

- Training in stress management and reduction; assertiveness; issues of sexism, racism, and class bias; and anger management
- Group, individual, and family counseling concerning sexual and physical abuse and their prevention
- Relationship and interpersonal skill building
- Personal care, issues of sexuality, and image enhancement
- Psychiatric and other mental health services, as needed by the woman, her children, and other family members

5Parenting and Family Services

- Planning and counseling for reunification with the patient's other children
- Counseling for women who wish to breastfeed regarding the risks to the infant of maternal drug use and from possible transmission of HIV; training in breastfeeding procedures, as appropriate
- Education about child and adult nutritional needs, food purchasing and preparation, and weight management
- Education about and training in child growth and development patterns
- Training in and support for nonpunitive child-rearing practices
- Assistance with and counseling about maternal and child bonding; participation in parental support groups
- Counseling for couples or significant others in communication, money management, crisis management, and parenting
- Counseling and intervention concerning child abuse and neglect, as needed
- Education about family systems, including information about cultures, traditions, and heritage
- Family therapy, as needed

## Guideline 2—Medical Stabilization and Withdrawal

The initial stabilization as well as the medical withdrawal of pregnant women from their drug(s) of abuse are recognized means of reducing the acute illness associated with the use of alcohol and other drugs. The initial stabilization of the patient should be accomplished within 10 days of first contact or earlier if medically necessary. The goals listed on next two pages may be attained by one agency or a collaboration of agencies within the community. The latter option requires appropriate cross-training between agencies.

During the period of stabilization, caregivers need to monitor the mother and fetus for adverse signs of drug withdrawal, establish a basis for ongoing alcohol and other drug treatment and recovery, and initiate a relationship between the mother and available supportive services within the community. The lead agency is generally responsible for assigning an appropriate staff person to undertake case management functions. The role of the case manager is to monitor and promote completion of this initial phase.

The procedures to be completed for the initial stabilization of pregnant, substance-using women are presented on the following two pages. They also apply to all of the specific medical withdrawal guidelines that follow.

Medical and Obstetrical Assessment

1 Follow universal precautions for blood and body fluids and Occupational Safety and Health Administration (OSHA) standards. Staff in health care facilities, especially those working with patients with histories of alcohol and other drug use, should be well versed in the appropriate application of the precautions and standards.

2 Obtain a detailed history and comprehensive physical examination that includes an obstetrical evaluation.

3 Conduct a laboratory evaluation, including but not limited to, complete blood count (CBC), sequential multichannel autoanalyzer (SMA) 18, serological test for syphilis, and urine analy-sis. Obtain results from the prenatal panel if they are available. If the woman is admitted before an initial prenatal examination has been performed, all prenatal laboratory tests should be done (see Guideline 8-Prenatal Intake).

4 Discuss HIV and document the discussion on the chart.

5 Obtain urine toxicologies or blood alcohol level tests as necessary (see Guideline 15-Urine Toxicology Considerations).

6 Perform fetal assessment, including a baseline sonogram, Non-Stress Tests (NSTs), or biophysical profiles appropriate for gestational age, as necessary.

7 Make other referrals as necessary.

Alcohol and Other Drug Use Assessment

1 Obtain a history of alcohol and other drug use, covering legal and illegal drugs (prescription drugs, over-the-counter drugs, alcohol, cigarettes), that includes

- Duration of use, including age of first use
- Frequency, type, amount, and periods of abstinence
- Routes of administration
- Social context of use (when, where, and with whom the patient uses)
- Past treatment history
- Support group involvement

2 Determine the consequences of alcohol and other drug use for the patient (self-perceived and objective).

3 Identify relapse factors for the patient.

4 Obtain a family history of alcohol and other drug use.

5 Assess the patient's motivation for treatment, including self-perceived and objective difficulties in entering treatment.

6 Assess the patient's motivation for continued use of alcohol and other drugs.

7 Obtain urine and/or blood toxicologies as needed (see Guideline 15-Urine Toxicology Considerations).

Psychosocial Assessment

1 Assess the patient's support systems, including her role in family and neighborhood support systems, and the stresses created by these systems.

2 Assess the patient's perception of her pregnancy and pregnancy options.

3 Assess the patient's educational level.

4 Assess the patient's employment skills.

5 Assess abuse and neglect experienced by the patient as an adult and as a child, including

- Sexual abuse
- Physical abuse and neglect
- Emotional abuse

6 Assess legal considerations and problems.

7 Assess current crises.

8 Assess the patient's current life and environmental situation, including

- Housing
- Transportation
- Child care
- Monetary support and assistance

9 Assess the patient's relationship to her other children.

Mental Health Assessment

1 Conduct a mental health evaluation that includes

- Mental status examination
- Psychiatric symptomatology
- Past psychiatric history and treatment
- Suicide risk
- Family psychiatric history
- DSM-III-R diagnosis
- Treatment recommendations

2 Use standardized psychiatric evaluation tools in diagnosis and followup.

3 Maintain liaison and ongoing contact with other members of the assessment and treatment team.

Alcohol and Other Drug Treatment Planning

1 Prepare a treatment plan with input from the patient and representatives from all participating health care and service agencies, that includes

- Appropriate alcohol and other drug treatment
- Medical and obstetrical care
- Followup services

2 Facilitate the introduction of the patient into alcohol and other drug treatment by contacting the patient at any point of entry for service or place of evaluation.

## Guideline 3—Medical Withdrawal From Alcohol ^11^ 11. Although there are separate sections addressing individual drugs, it is important to recognize that many women will use more than one drug. Polydrug abuse is the norm, not the exception.

It should be assumed that pregnant women who consume over 8 ounces of [absolute] alcohol (1 pint of liquor) daily have developed tolerance. ^12^ However, tolerance may develop at lower levels of consumption in some women and in women using multiple drugs.

12. Jessup, M., and Green, J.R. Treatment of the pregnant alcohol-dependent woman. Journal of Psychoactive Drugs 19(2):193-203, 1987.

The sudden cessation of drinking can result in withdrawal symptoms, some of which may be threatening to the mother and the fetus. It is imperative that medical withdrawal of an alcohol-dependent, pregnant woman be conducted in an inpatient setting and under medical supervision that includes collaboration with an obstetrician. These conditions will ensure

- Close observation and monitoring of maternal alcohol withdrawal status
- Continual monitoring of fetal well-being

Most programs choose to treat the pregnant, alcohol-dependent woman with short-acting barbiturates or benzodiazepines. Chlordiazepoxide (Librium) and other benzodiazepines, such as diazepam (Valium) and barbiturates (Phenobarbital, Seconal), are valuable for symptomatic treatment during medical withdrawal from alcohol. They are also potentially teratogenic. Some clinicians, therefore, recommend avoiding their use if at all possible. The risks versus the possible benefits of their use need to be assessed.

Disulfiram (Antabuse) is contraindicated during pregnancy. Its use has been associated with clubfoot, VACTERL syndrome (a pattern of congenital anomalies), and phocomelia of the lower extremities. ^13^ The woman who conceives while taking this drug should receive counseling before deciding to continue the pregnancy.

13. Jessup, M., and Green, J.R. Treatment of the pregnant alcohol-dependent woman. Journal of Psychoactive Drugs 19(2):193-203, 1987.

Symptoms of Alcohol Withdrawal

Early symptoms of alcohol withdrawal generally appear 6 to 48 hours after drinking has stopped but can occur up to 10 days after the last drink. Withdrawal symptoms may include

- Restlessness
- Tachycardia
- Irritability
- Hypertension
- Anorexia
- Insomnia
- Nausea
- Nightmares
- Vomiting
- Impaired concentration
- Sweating
- Impaired memory
- Tremor
- Elevated vital signs

More severe symptoms of alcohol withdrawal may include

- Increased tremulousness
- Increased agitation
- Increased sweating
- Delirium (with confusion, disorientation, impaired memory and judgment)
- Hallucinations (auditory, visual, or tactile)
- Delusions (usually paranoid)
- Grand mal seizures

Note: Withdrawal symptoms do not necessarily progress from mild to severe. In some individuals, a grand mal seizure may be the first sign of withdrawal. Seizures usually occur 12 to 24 hours after cessation or reduction of drinking. One-third of all patients who have seizures develop delirium tremens.

### Maternal and Fetal Effects of Alcohol

Alcohol use during pregnancy may be associated with a variety of serious health consequences for the woman, the fetus, and the subsequent infant.

1Possible maternal complications of excessive alcohol consumption:

- Nutritional deficiencies
- Pancreatitis
- Alcoholic ketoacidosis
- Precipitate labor
- Alcoholic hepatitis
- Deficient milk ejection
- Cirrhosis

2Possible effects on the fetus:

- Fetal Alcohol Syndrome (FAS)
  - prenatal/postnatal growth retardation
  - central nervous system deficits, including developmental delay and neurological/intellectual impairments
  - facial feature anomalies, including microcephaly
- Fetal Alcohol Effects (FAE)
  - cardiac abnormalities
  - neonatal irritability and hypotonia
  - hyperactivity
  - genitourinary abnormalities
  - skeletal and muscular abnormalities
  - ocular problems
  - hemangiomas
- No effect

### Guidelines for Medical Withdrawal From Alcohol

#### Procedures at the Time of Admission

1 Obtain a detailed health history, including alcohol and other drug use and arrangements for prenatal care.

2 Conduct a comprehensive physical examination, including weight, vital signs, and an obstetrical evaluation.

3 Obtain laboratory tests, including: a) Initial blood workup that includes, but is not limited to

- Blood group, Rh factor determination, and antibody screen
- Serological test for syphilis
- Hepatitis B and C screens
- Complete blood count with indices

b) Other initial laboratory tests that include, but are not limited to

- Cervical cytology smear (Pap smear), unless the provider has results of a test performed within the past 3 months
- Cervical culture for gonorrhea
- Urine screen for urinary tract infection, kidney disease, protein, and glucose
- Chlamydia screen

4 Obtain purified protein derivative of tuberculin (PPD) test with antigen panel.

5 Obtain urine and/or blood toxicologies (see Urine Toxicology Considerations).

6 Provide for HIV antibody counseling and testing.

7 Obtain baseline sonogram if appropriate.

#### Dosing Strategy

1 Evaluate the pattern, frequency, and amount of alcohol and other drug use.

2 Obtain a detailed history of alcohol and other drug use within the past 24 hours and of any previous alcohol withdrawal reaction.

3 Begin initial treatment with thiamine, folic acid, and prenatal iron and vitamins. Obtain laboratory tests listed above, including CBC, electrolytes, and magnesium level and, when indicated, obtain an electrocardiogram (EKG).

4 Obtain an initial blood alcohol level to determine

- Extent of intoxication at admission
- Safe time to begin medication
- Expected time for full withdrawal to begin. The usual rate of elimination of alcohol from a healthy alcohol dependent person is 30 mg/dl/hr. This rate may be increased during pregnancy.

5 Provide for nonpharmacological interventions designed to

- Reduce stimuli
- Maintain hydration
- Maintain reality orientation
- Provide reassurance and positive reinforcement
- Provide nutritional support
- Maintain physical comfort
- Maintain body temperature
- Encourage sleep and rest

6 Follow withdrawal schedule. Programs use different drugs to withdraw patients from alcohol. Drugs used include chlordiazepoxide, phenobarbital, and diazepam.

- Typical withdrawal schedules using chlordiaze-poxide include 25 to 50 mg 4 times a day for the first 2 days, decreasing gradually to 10 mg 4 times a day for days 8 through 10.
- Typical withdrawal schedules using phenobarbital include 15 to 60 mg by mouth every 4 to 6 hours as needed for the first 2 days, decreasing gradually to 15 mg by the 4th day.
- Typical withdrawal schedules using diazepam include 10 mg 4 times a day; 10 mg every 2 hours as needed for withdrawal symptoms with a maximum of 150 mg/24 hours; decreasing gradually at a rate of 20 to 25 percent over approximately 5 days.
- The loading dose protocol with diazepam is accomplished with doses given according to withdrawal symptomatology. When withdrawal symptoms are stabilized, the long half-life of diazepam alleviates the need for further medication in most cases.

7 Monitor for signs and symptoms of alcohol withdrawal syndrome (AWS). The use of withdrawal assessment scales can be valuable in determining the need for further medication. Monitor for the following:

- Vital signs (temperature, blood pressure, pulse)
- Delirium (orientation)
- Wernicke's encephalopathy (nystagmus)
- Psychosis (hallucinations, inappropriate thinking)
- Irritability (tremors, increased reflexes)
- Increased autonomic reflexes (goosebumps, sweating)
- Fetal well-being (fetal heart tones, sonograms, or Non-Stress Test) as appropriate for gestational age

8 Reduce medication dose if the patient shows signs of oversedation.

9 Provide for positive social support for the patient to help manage stress.

10 Discharge the patient after medical withdrawal to the care of a case manager for continuing treatment and prenatal care.

## Guideline 4—Opioid Stabilization ^14^ 14. Stabilization refers to maintenance or medical withdrawal.

The following approaches are used to manage the pregnant, opioid-addicted woman. The first approach is methadone maintenance combined with psychosocial counseling. This is a well-documented approach to improve outcomes for both the woman and her fetus.

The second approach is slow medical withdrawal with methadone. The safety of this second approach has not been documented.

Opioid Withdrawal Signs and Symptoms

Mild withdrawal signs and symptoms include

- Generalized anxiety
- Opioid craving
- Restlessness
- Slight aching of muscles, joints, and bones
- Lower back pain

Mild to moderate withdrawal signs and symptoms include

- Tension
- Yen sleep (mild insomnia)
- Mydriasis (pupils dilated)
- Lethargy
- Diaphoresis (increased perspiration)

Moderate withdrawal signs and symptoms include

- Chills alternating with flushing and diaphoresis (sweating)
- Nausea and/or stomach cramps
- Rhinorrhea (runny nose)
- Moderate aching of muscles, joints, and bones
- Lower back pain
- Anorexia
- Nausea and/or stomach cramps
- Yawning
- Lacrimation (tearing)
- Goose flesh (earlier if client is in a cold, drafty room)
- Elevated pulse and blood pressure

Moderate to severe withdrawal signs and symptoms include

- Diarrhea
- Vomiting
- Tremors
- Tachycardia (pulse over 100 BPM)
- Increased respiratory rate and depth

Severe withdrawal signs and symptoms include

- Doubling over with stomach cramps
- Kicking movements
- Elevated temperature (usually low grade, less than 100° F)

Note: Withdrawal signs and symptoms differ in their order of appearance from one individual to another. Some individuals may not exhibit certain withdrawal signs and symptoms. Signs may also include uterine irritability, increased fetal activity, or rarely, hypotension.

### Symptoms of Opioid Withdrawal Syndrome

Despite its dramatic appearance, the opioid withdrawal syndrome is rarely life-threatening or permanently disabling to an adult. However, there is good evidence that the fetus may be more susceptible to withdrawal symptoms than the mother. In the mother, the initial signs of opioid withdrawal progress to increasingly painful physical symptoms. In addition to these signs, patients show compelling psychological cravings for drugs, as well as drug-seeking behavior.

Methadone substitution is the standard treatment for heroin addiction. Methadone treatment alternatives consist of (1) high-dose blockage; (2) low-dose maintenance; and (3) medical withdrawal.

Medical withdrawal of the opioid-dependent woman is not recommended in pregnancy because of the increased risk to the fetus of intrauterine death. Methadone maintenance is the treatment of choice. In addition to methadone maintenance, a comprehensive approach is needed that will provide the patient with counseling and other services.

The administration of methadone, combined with any opioid agonist/antagonist such as pentazocine (Talwin), will precipitate withdrawal. ^15^ Any pregnant woman receiving methadone should be advised against taking opioid agonist/antagonists under all circumstances.

15. Finnegan, L.P. Treatment issues for opioid-dependent women during the perinatal period. Journal of Psychoactive Drugs 23(2):191-201, 1991.

Neonatal abstinence syndrome (NAS) may or may not be related to maternal dose of methadone; NAS may also be related to fetal gestational age and infant weight. However, studies in both pregnant women and other adults have shown that larger doses of methadone result in a decreased use of other drugs.

### Maternal and Fetal Effects of Opioids

These effects may be the result of concomitant maternal lifestyle factors rather than the direct result of drug use.

1Possible effects on the pregnancy:

- Toxemia
- Intrauterine growth retardation
- Miscarriage
- Premature rupture of membranes
- Infections
- Breech presentation (abnormal presentation due to premature delivery)
- Preterm labor
- No effect

2Possible effects on the mother:

- Poor nourishment, with vitamin deficiencies, iron deficiency anemia, and folic acid deficiency anemia
- Medical complications from frequent use of dirty needles (abscesses, ulcers, thrombophlebitis, bacterial endocarditis, hepatitis, and urinary tract infection)
- Sexually transmitted diseases (gonorrhea, chlamydia, syphilis, herpes, and HIV infection)
- Hypertensive disorder
- No effect

3Possible effects on the fetus and newborn infant:

- Low birth weight
- Prematurity
- Neonatal abstinence syndrome
- Stillbirth
- Sudden infant death syndrome
- No effect

### Opioid Conversion and Methadone Stabilization

The goal of the methadone strategy is to stabilize the patient without producing any indication of opioid abstinence syndrome.

#### Procedures at the Time of Admission

1 Obtain a detailed health history, including alcohol and other drug use and arrangements for prenatal care.

2 Conduct a comprehensive physical examination, including weight, vital signs, and an obstetrical evaluation.

3 Obtain laboratory tests, including

a) Initial blood workup that includes, but is not limited to

- Blood group, Rh factor determination, and antibody screen
- Serological test for syphilis
- Hepatitis B and C screens
- Complete blood count with indices

b) Other initial laboratory tests that include, but are not limited to

- Cervical cytology smear (Pap smear), unless the provider has results of a test performed within the past 3 months
- Cervical culture for gonorrhea
- Urine screen for urinary tract infection, kidney disease, protein, and glucose
- Chlamydia screen

4 Obtain purified protein derivative of tuberculin (PPD) test with antigen panel.

5 Obtain urine and/or blood toxicologies (see Guideline 15 -- Urine Toxicology Considerations).

6 Provide for HIV antibody counseling and testing.

7 Obtain baseline sonogram if appropriate.

#### Methadone Dosing Strategy

Determine the amount of drug being used and follow the dosing strategy listed below.

1 Evaluate the pattern of drug use, route of administration, and frequency and amount of drug use. Know something about the purity of the street product and the other substances, such as quinine or Valium, with which the product may be cut or diluted.

2 Obtain a detailed history of drug use within the past 24 hours.

3 Give an initial oral methadone dose of 10 to 40 mg. Because it is imperative to reverse any opioid abstinence symptoms as quickly as possible, an additional dose of methadone may be required in the range of 5 to 10 mg if objective signs of withdrawal persist after 3 to 4 hours (time to allow the methadone to reach a peak blood level). This 5- to 10-mg dose can be repeated at 3 to 4 hour intervals until objective signs of withdrawal are no longer present.

4 Adjust the dosage by 5 to 10 mg daily based on physical signs and symptoms of opioid withdrawal (see table) and patient comfort. Even minimal symptoms in the mother may indicate stress in the fetus.

5 After the stabilization dose has been established, keep the patient at this level for several days.

6 If there is simultaneous dependence on other drugs such as alcohol, cocaine, and sedatives, methadone induction should proceed as outlined in items 1 through 5, while concurrent medical withdrawal procedures are initiated. The other drug withdrawals can be managed as usual against the background of methadone maintenance. Ideally, this is an inpatient procedure.

Important Warning: NARCAN (or any narcotic antagonist) should never be given to a pregnant, substance-using woman except as a last resort to reverse severe narcotic overdose. Administration of a narcotic antagonist to a pregnant, substance-using woman could result in spontaneous abortion, premature labor, and/or stillbirth. ^16^

16. Providence Hospital, Inc., Elm Street Health and Human Services Center. Pregnant Addicts Protocol: Methadone Stabilization. Holyoke, MA: Providence Hospital, Inc., n.d.

### Guidelines for Methadone Maintenance

Methadone maintenance is strongly encouraged for all pregnant, opioid-dependent women. It provides the following advantages:

- Reduces illegal opioid use as well as use of other drugs
- Helps to remove the opioid-dependent woman from the drug-seeking environment and eliminates the necessary illegal behavior
- Prevents fluctuations of the maternal drug level that may occur throughout the day
- Improves maternal nutrition, increasing the weight of the newborn
- Improves the woman's ability to participate in prenatal care and other rehabilitation efforts
- Enhances the woman's ability to prepare for the birth of the infant and begin homemaking
- Reduces obstetrical complications

There are no specific guidelines established for methadone dosages for pregnant women. In general, the clinical trend is toward use of an individually determined, most effective dose that is adequate to prevent withdrawal symptoms.

The following guidelines have been used for pregnant and nonpregnant substance users: 1 The high-dose methadone blockage dosage is between 50 and 150 mg per day. 2 The low-dosage methadone maintenance dosage is less than 60 mg per day.

Based on current and emerging research, the National Institute on Drug Abuse (NIDA) suggests that maintenance doses below 60 mg are not effective and hence not appropriate. ^17^ Arbitrary low-dose policies for pregnant and nonpregnant patients is often associated with increased drug use as well as reduced program retention. Based on current informed consensus, the most prudent course is to rely on individually determined methadone dosing that is measured by the absence of subjective and objective abstinence symptoms and the reduction of drug hunger.

17. Pond, S.M.; Kreek, M.J.; Tong, T.G.; Raghunath, J.; and Benowitz, N.L. Altered methadone pharmacokinetics in methadone-maintained pregnant women. Journal of Pharmacology and Experimental Therapy 233:1-6, 1985.

An increased methadone dosage may be needed in later stages of pregnancy to prevent withdrawal. (The greater plasma volume and renal blood flow of pregnancy can contribute to a reduced level of methadone in the blood. As a result, the woman's maintenance dose may be insufficient to prevent cravings.) Either administer methadone twice a day to give a more even blood level throughout the day or raise the single daily dose.

### Guidelines for Medical Withdrawal From Methadone

Medical withdrawal of the pregnant, opioid-dependent woman from methadone is not indicated or recommended. Few women will have the motivation or the psychosocial supports to accomplish and maintain total abstinence. The goal, therefore, is to achieve the best therapeutic dose possible with which the woman feels comfortable. The neonatal abstinence syndrome can be treated with minimal complications.

Despite the above caution, at times, medical withdrawal may need to be considered due to logistical or geographic barriers. In these cases, the decision to undertake such a program must be a joint decision between the obstetrician, the woman, and her counselor, with the understanding that few women will be appropriate candidates for this approach.

The woman should understand that she must prove she is a candidate for medical withdrawal by complying with prenatal and therapy appointments and supplying clean urines. If at any time the woman is unable to comply with these requirements, no further decrease in dosage of methadone should be ordered.

1Timing of withdrawal. There are no research data that suggest withdrawal in one trimester is worse than in others. Some clinical practitioners indicate concerns regarding methadone withdrawal prior to 14 weeks or after 32 weeks. These concerns are based on the theoretical possibility of an increased incidence of spontaneous abortion and premature labor. Other clinicians believe that withdrawal can be performed in all trimesters.

Patients should be allowed to discontinue withdrawal at any time, for any reason, without feelings of guilt. They should then be placed into a methadone maintenance program at a therapeutically sound dose. Clinicians need to be particularly aware that a decrease in methadone dosage could precipitate a relapse to drug use. Patients in continuous treatment who return to illegal drug use should be placed back on methadone. Methadone is preferable to the use of illegal street drugs.

2Withdrawal schedule. Medical withdrawal from methadone is usually done in decrements of 2 to 2 1/2 mg every 7 to 10 days. This procedure should only be done in conjunction with an obstetrician who can monitor the effects on the fetus. Intrauterine demise (death of the fetus in utero) has been documented as a complication of medical withdrawal even when done under optimal conditions, such as hospitalization and close fetal monitoring.

Note: At the time of publication, there was no protocol for medical withdrawal from methadone that had been evaluated in an appropriate number of women with suitable scientific and medical rigor.

### Opioid Withdrawal Using Clonidine

The long-term effects of the use of clonidine in pregnancy are still unknown. Although clonidine hydrochloride has been used safely and effectively for rapid medical withdrawal in the management of opioid withdrawal in nonpregnant, opioid-dependent individuals, ^18^ there are no data concerning its safety in pregnancy. Further research in this area needs to be performed before this technique can be recommended as a standard of care for pregnant women.

18. American Hospital Formulary Service. AHFS Drug Information 90. Bethesda, MD: AHFS, 1990.

## Guideline 5—Cocaine Withdrawal

There are no well-documented studies regarding the safety or efficacy of using drugs to medically withdraw pregnant, cocaine-using women. The evidence is extremely limited for all methods of medical withdrawal. Inpatient treatment is the ideal whenever possible, although these facilities may not always be available. Medical withdrawal is just the first step in the continuum of care for pregnant, cocaine-dependent women. Referral to ongoing alcohol and other drug treatment and relapse prevention services is essential.

Symptoms of Cocaine Withdrawal

Withdrawal from cocaine dependence is characterized by depression, anxiety, and lethargy, which begin to resolve after approximately 1 week. Less common are signs of a paranoid psychosis during withdrawal from chronic use of high doses of cocaine. In cocaine withdrawal, medication is rarely needed for the serious sequelae that are associated with alcohol, barbiturate, and opioid withdrawal.

### Maternal and Fetal/Infant Effects of Cocaine

1Possible effects of maternal cocaine use during pregnancy:

- Intrauterine growth retardation (IUGR)
- Abruptio placentae
- Premature labor
- Spontaneous abortion
- No effect

2Possible effects on the fetus and newborn infant that have been reported:

- Increased congenital anomalies
- Mild neurodysfunction
- Transient electroencephalogram abnormalities
- Cerebral infarction and seizures
- Vascular disruption syndrome
- Sudden infant death syndrome
- Smaller head circumference
- No effect

### Guidelines for Withdrawal From Cocaine: Treatment Options

There are no data about the effectiveness of the following guidelines in pregnancy. In those guidelines that substitute other drugs, many of the drugs are problematic to the newborn and some have not been confirmed to be safe. Some centers do not generally use antidepressants for cocaine withdrawal depression. However, other programs prescribe antidepressants for the first 5 days to try to reduce the high dropout rate that occurs during this period. Sedatives and/or antidepressants may cause excessive drowsiness in a cocaine-dependent woman.

Cocaine-dependent women who require sedatives and/or antidepressants for any significant length of time often have an endogenous depressive disorder. Psychiatric consultation is usually indicated.

#### Procedures at the Time of Admission

1 Obtain a detailed health history, including alcohol and other drug use and arrangements for prenatal care.

2 Conduct a comprehensive physical examination, including weight, vital signs, and an obstetrical evaluation.

3 Obtain laboratory tests, including

a) Initial blood workup that includes, but is not limited to

- Blood group, Rh factor determination, and antibody screen
- Serological test for syphilis
- Hepatitis B and C screens
- Complete blood count with indices

b) Other initial laboratory tests that include, but are not limited to

- Cervical cytology smear (Pap smear), unless the provider has results of a test performed within the past 3 months
- Cervical culture for gonorrhea
- Urine screen for urinary tract infection, kidney disease, protein, and glucose
- Chlamydia screen

4 Obtain purified protein derivative of tuberculin (PPD) test with antigen panel.

5 Obtain urine and/or blood toxicologies (see Guideline 15 -- Urine Toxicology Considerations).

6 Provide for HIV antibody counseling and testing.

7 Obtain baseline sonogram if appropriate.

#### Dosing Strategy

Determine the amount of drug being used and follow the dosing strategy listed below.

1 Evaluate the pattern of drug use, route of administration, and frequency and amount of drug use.

2 Obtain a detailed history of drug use within the past 24 hours.

To withdraw a pregnant woman dependent on cocaine, the following are options.

1 No medications. Pregnant patients who are withdrawing from cocaine should not be medicated except in cases of extreme agitation and by individual order of the health care provider.

2Anxiolytics. If medication is needed, low doses of diazepam (Valium) or chlordiazepoxide (Librium) (25 mg by mouth, 4 times a day, x 6 doses) may be used.

3Antidepressants. A typical withdrawal guideline for cocaine-dependent women uses doxepin (Sinequan) or desipramine (Norpramin). For example,

- Days 1-2: Doxepin 25 mg (one tablet) by mouth 2 times a day, 50 mg maximum.
- Days 3-5: Doxepin 25 mg (one tablet) by mouth 2 times a day, then discontinue.
- Further therapy should be determined by the treating physician after an initial period of observation.
- No drug therapy is usually indicated after the first 5 days.

4Barbiturates. For cocaine withdrawal symptoms:

- Days 1-2: Phenobarbital 30 to 60 mg every 4 hours as needed.
- Days 3-4: Phenobarbital 30 to 60 mg every 6 hours as needed.

5Bromocriptine. Bromocriptine, a drug used to treat menstrual abnormalities and infertility in women, has provided striking and consistent relief from cocaine craving among inpatients.

Research indicates that cocaine, when used by the first-time user, seems to stimulate dopamine and also blocks the reuptake of dopamine, which produces the cocaine high. The brains of regular users of cocaine cannot make dopamine as quickly as the cocaine demands; the result is an eventual depletion that creates the crashing and craving effects.

The use of bromocriptine in pregnancy is not recommended because of the lack of proven efficacy and unknown effects, both short and long term, on the fetus.

6Acupuncture. Acupuncture has been used in the treatment of cocaine addiction. Traditional use of acupuncture for other disorders has usually been contraindicated in pregnancy. At the time of publication, the National Institute on Drug Abuse has not concluded its evaluation of the efficacy of this treatment.

## Guideline 6—Sedative-Hypnotic Medical Withdrawal

Inpatient medical withdrawal from barbiturates, benzodiazepines, and other sedative-hypnotic drugs is recommended because continual monitoring of the mother and the fetus is required. Drug doses must be tapered so that mother and fetus arrive at a drug-free state without experiencing an uncontrolled withdrawal.

Barbiturates and benzodiazepines are the most commonly abused sedative-hypnotics. There are marked similarities between the withdrawal syndromes seen with both of these drugs. Patients abruptly withdrawn from large doses of benzodiazepines may sustain withdrawal symptoms that closely resemble those associated with barbiturate physical dependence. Because of these similarities, only the barbiturate abstinence syndrome is presented in this guideline.

Symptoms of Barbiturate Abstinence Syndrome

The barbiturate abstinence syndrome begins 6 to 24 hours after the last dose, and symptoms are generally more severe with the short-acting barbiturates. Signs and symptoms of barbiturate abstinence include

- Tremulousness
- Diaphoresis
- Anxiety
- Postural hypotension
- Insomnia
- Grand mal convulsions (between days 3 and 7)
- Agitation
- Anorexia
- Delirium
- Nausea and vomiting
- Tendon hyperreflexia

If untreated, withdrawal symptoms can progress to hyperpyrexia, electrolyte abnormalities, cardiovascular collapse, and death.

### Guidelines for Withdrawal From Sedative-Hypnotic Drugs

The following recommendations are meant to be generic, to allow individual guidelines to be designed for specific treatment settings.

#### Management of Withdrawal

Management of withdrawal in patients who may or may not be pregnant can include

- Substitution of a long-acting agent (phenobarbital, diazepam, clonazepam), and subsequent withdrawal of this agent
- Slow withdrawal of the addicting agent

##### Risk categories for severe withdrawal

- Low risk: Sporadic use of a drug or use for relief of cocaine-induced anxiety or insomnia.
- Moderate risk: Daily use of a drug for at least 2 to 4 months at a therapeutic level; concomitant alcohol abuse at low doses; history of mild withdrawal symptoms.
- High risk: Prolonged daily use of a drug at higher than therapeutic doses; higher use of alcohol; history of serious withdrawal symptoms.
- Highest risk: Previous withdrawal seizures or a history of a seizure disorder that is exacerbated by sedative-hypnotic withdrawal.

##### Some considerations for withdrawal from sedative-hypnotic drugs during pregnancy

- Severe withdrawal from barbiturates can produce status epilepticus and maternal and fetal respiratory arrest. Immediate obstetrical intervention and hospitalization are warranted.
- Use of dilantin and other anticonvulsants have been considered for a patient with a history of withdrawal seizures. However, these drugs have been associated with congenital anomalies. Therefore, their use in pregnancy must be based on an assessment of the risks versus the benefits. Although there are concerns of teratogenicity regarding benzodiazepines and barbiturates, these appear to have a lower risk versus benefit ratio.

#### Procedures at the Time of Admission

1 Obtain a detailed health history, including alcohol and other drug use and arrangements for prenatal care.

2 Conduct a comprehensive physical examination, including weight, vital signs, and an obstetrical evaluation.

3 Obtain laboratory tests, including

a) Initial blood workup that includes, but is not limited to

- Blood group, Rh factor determination, and antibody screen
- Serological test for syphilis
- Hepatitis B and C screens
- Complete blood count with indices

b) Other initial laboratory tests that include, but are not limited to

- Cervical cytology smear (Pap smear), unless the provider has results of a test performed within the past 3 months
- Cervical culture for gonorrhea
- Urine screen for urinary tract infection, kidney disease, protein, and glucose
- Chlamydia screen

4 Obtain purified protein derivative of tuberculin (PPD) test with antigen panel.

5 Obtain urine and/or blood toxicologies (see Guideline 15 -- Urine Toxicology Considerations).

6 Provide for HIV antibody counseling and testing.

7 Obtain baseline sonogram if appropriate.

#### Dosing Strategy

Determine the amount of drug being used and follow the dosing strategy listed below.

1 Evaluate the pattern, frequency, and amount of drug use.

2 Obtain a detailed history of drug use within the past 24 hours.

3 Document signs and symptoms of withdrawal. The regular use of a standardized withdrawal assessment scale can be helpful.

4 Administer drugs for medical withdrawal. The drugs used for medical withdrawal may vary. For medical withdrawal of patients dependent on barbiturates, minor tranquilizers, or other sedatives, some programs suggest administering the drug of use. The use of a long-acting drug, such as phenobarbital, diazepam, or clonazepam, may be helpful.

5 Stabilize the patient to suppress withdrawal symptoms. Supportive measures should include a safe environment with proper nutrition and rest. Frequent reassurance and encouragement are vital.

6 Withdraw the pregnant patient in regular decrements of from 5 to 10 percent of dose daily.

## Guideline 7—Mental Health Considerations

Mental disorders in pregnant, substance-using women often go undetected by health care providers and alcohol and other drug treatment staff. It is essential that a dual diagnosis be made, when appropriate, and addressed in subsequent treatment planning. The complex combination of pregnancy, addiction, and mental illness requires a carefully coordinated approach. The following general guidelines can be useful in assessing the mental health of pregnant, substance-using women.

### Mental Health Assessment ^19^ 19. Sanchez, L. Pregnancy, addiction and mental health. In: A Guide to the Detoxification of Alcohol and Other Drug-Dependent Pregnant Women. Cambridge, MA: Coalition on Addiction, Pregnancy, and Parenting, 1991.

- Distinguish between drug-induced psychiatric symptoms and a major mental disorder. Symptoms such as anxiety, agitation, and paranoia can be manifestations of a state of drug intoxication or of the withdrawal syndrome itself and at times require no medications. Ongoing psychosocial support may help minimize many of these symptoms.

@BULLET TEXT = On the other hand, confirmed mental illness may necessitate the continuation of medications, such as antidepressants or antipsychotics, which have been previously effective in treating the underlying disorder. It is mandatory that a diagnosis of mental illness be ruled out before such medication is stopped. It must be remembered that evidence is inconclusive regarding the safe use of any psychotropic medication in pregnant women. A thorough assessment of the risks versus the benefits must be made prior to administering these medications.

- Establish any previous history of psychiatric illness before developing the medical withdrawal treatment plan. Efforts should be made to contact previous therapists, treating agencies, and mental health facilities for this crucial information.
- Establish communication early in treatment with mental health personnel involved in the patient's care. These individuals often can provide important history, help build an alliance with the patient, support discharge planning, and provide assistance in the event of an acute management crisis.
- Individualize medical withdrawal plans for each patient. Carefully review standard guidelines and amend them if there are significant psychiatric problems to be treated.
- Set up arrangements to involve mental health personnel, where appropriate, in establishing diagnoses and in developing the treatment plan.
- Continue prescribed medications and provide appropriate followup for patients who enter alcohol and other drug treatment programs with well-documented, diagnosed psychiatric illnesses that require psychopharmacologic medication.
- Continue any prescribed medications, such as methadone and chlordiazepoxide, except as advised by the patient's health and mental health care providers. Patients should be supported in this decision by treatment programs. Some support groups may inappropriately encourage women to abandon all medications.
- Do not avoid seeking therapy for the patient because of the complex combination of pregnancy, addiction, and psychiatric problems. Careful planning and staff coordination are usually effective in treatment.
- Use well-validated psychiatric assessment scales in the diagnosis and followup of individual patients (see Appendix B).
- Consider issues of codependency, adult children of alcoholics/other addictions, and deep trauma from childhood in the evaluation of patients.

### Guidelines for Medical Withdrawal

Orders for medication should be individualized to minimize the types and doses prescribed. Psychotropic drugs may need to be prescribed throughout medical withdrawal. The use of psychotropic drugs must be considered on a case-by-case basis, taking into consideration their effects on the mother and fetus, particularly with respect to interactions with methadone and possible congenital abnormalities. Behavioral management techniques should be developed to minimize the need for these medications. Providing adequate staff, structure, limits, and support are important treatment methods.

### Other Issues

Agitation and oppositional or impulsive behavior can be manifestations of cognitive impairments, such as attention deficit disorder, limited intelligence, mild retardation, or psychotic illness. Patients with these behaviors can appear to have difficulty comprehending or complying with treatment expectations. Awareness of these deficits can help staff manage these problems and adapt treatment methods to minimize or avoid unnecessary confrontations.